# Appendixes

Appendix A References Dataset 1: Back Pain, 216 Trials

Appendix B References Dataset 2: EPC Reports, 165 Trials

Appendix C References Dataset 3: Published “Pro-bias” Dataset, 100 Trials

Appendix D Comparison Fixed-Effects Model Results

Appendix E Comparison Random Effects Meta-regression Results

Appendix F Quality Rating Form