# Acknowledgements

We would like to thank the Tufts Medical Center and the Research Triangle Institute – University of North Carolina (RTI-UNC) Evidence-based Practice Center for their collaboration in identifying EPC reports and Kirstin Nyrop and Jonathan V. Todd for quality scoring of selected articles. We also thank Ethan Balk, Nancy Berkman, Isabelle Boutron, Tim Carey, Mark Helfand, David Moher, and Sydne Newberry for comments on an earlier draft of this report.