# Results

## Decisionmaking Contexts—Why Are Stakeholders Interested in Economic Evaluation Data?

Decisionmaking contexts for pharmaceuticals begin with regulatory approval of new drugs or devices on safety grounds. Other decisionmaking contexts start with a choice of a manufacturer to develop a new device or the choice of a practice to develop a new intervention. They also include decisions to cover specific services and decisions on how much to reimburse for specific services. At health care facilities, adoption or nonadoption and utilization decisions will be driven by economic criteria, i.e., profit maximization. Health care providers will focus primarily on utilization decisions. Patients are interested in the utilization of specific interventions or treatments to improve their health. We are interested in economic data alongside a systematic review of evidence to place the effectiveness in context of the resources that are required to achieve it so that individuals, organizations, and society can decide whether to make the investment or not.

While contexts are frequently changing and being modified by new alternatives that are available in the market and new budget constraints, we can summarize decisionmaking contexts as follows.

- Approval and monitoring: This type of decision is at the level of a regulatory body responsible for ensuring patient safety. Such decisions are most frequently for safety and do not involve economic criteria.
- Formulary inclusion: Formulary inclusion focuses on coverage of pharmaceutical products and may be at the level of the third-party payer (public or private) or the level of a hospital. The formulary decision may be a decision to include or exclude but may also be a decision about the tier on which to place a particular item, i.e., most favorable coverage or less favorable coverage for consumers. This decision requires economic data, ideally on cost-effectiveness and the price elasticity of demand for the product in question, as well as the price elasticity of demand for complements and substitutes.
- Insurance coverage decision: Insurance coverage decisions are separate from formulary decisions because insurance coverage decisions include far more than only pharmaceutical products. Formulary decisions can be only about whether something should be on the formulary list, but also can be to place an item on a particular formulary tier. Insurance coverage decisions are about whether something should be paid for by the insurer. In addition, insurers make decisions about how much to pay for services; these are reimbursement decisions that can create incentives for use of the items or treatment options. Such decisions call for data on cost-effectiveness, the price elasticity of the service or product in question, and the cross-price elasticity of substitutes and complements. These types of data are useful in making insurance coverage decisions and in allowing insurers to anticipate how the change in coverage will impact predicted expenditures and, ultimately, premiums.
- Reimbursement rate: The reimbursement rate focuses on the amount that will be paid to the providers of care or the facilities in which the providers operate. This type of decision is usually made along with the decisions about whether a new technology or procedure should be covered and what the patient will be expected to pay out of pocket to generate an entire system of incentives. This clearly involves an entire set of economic data on incentives and potentially on cost-effectiveness if the desire is to direct consumers and providers to use specific treatments.
- Preferred practice guideline: Preferred practice guidelines are often developed by professional associations, but could be developed by other bodies within the health care system. These guidelines are often outside of the context of economic constraints, and focus more on patient well-being or more narrowly defined patient health.
- Technology or nonadoption: Decisions about technology or nonadoption are being made at the level of the provider. Decisions may be made by a large health care facility. Large facilities may choose to adopt multiple technologies, and the economics are especially important for portfolios of technology. Decisions also may be influenced by the relationship between a physician's office and any facilities with which the practice is associated if the facility already has the technology.
- Clinical Management: Clinical management refers to the physician-patient dyad decisionmaking about specific services to use to address medical issues that a patient faces. A subset of this is treatment adherence that reflects decisions made by the patient and perhaps the patient's family. Decisions to continue to use and follow the directions for use of specific medical interventions (e.g., the appropriate use of eye drops to reduce intraocular pressure for patients with glaucoma) are at least partially based on economic criteria. Whether the physician typically asks about economic issues or the patients feel comfortable sharing economic issues with the physician are issues that require empirical analysis.

More than one decisionmaking context may be relevant to any specific stakeholder. For example, although the adherence issue most directly involves the patient, the family, and consumer organizations, all stakeholders should be interested in adherence as it usually will affect the economics and the outcomes. Similarly, while the patient is most directly involved in the adherence decisionmaking context, the patient will have an interest in coverage decisions and the amount that will be reimbursed. These different decisionmaking considerations can be applied to pharmaceutical products, imaging devices, or any other type of medical intervention.

## When Should Economic Evaluation Data Be Requested in a Systematic Review?

The health economist focused on efficiency and making decisions under perfect information might say that economic evaluation data should always be included when a systematic review is being performed to help stakeholders make informed decisions. As long as there is a decision that could be made or changed based on the review, it is never too late to consider inclusion of economic data. Frequently, however, the resources available do not allow for all data to be integrated into a systematic review.

Several criteria can be used to determine whether or not to request inclusion of economic evidence in a systematic review of a medical intervention. These include the expected incremental cost of the intervention, the expected incremental efficacy of the intervention, and the likelihood that the magnitude of expenditures will affect decisions about use of an intervention. While a reason for any review is, in part, to determine just how large the incremental costs and incremental effects are, policymakers are likely to have prior beliefs about what the expected incremental values are. If policymakers do not have prior beliefs themselves, consultation with experts can help to provide insight on the expected changes that can then be used to motivate, in part, the need to gather economic data alongside a systematic review of effectiveness.

Part of the last consideration is whether the intervention fits within the budget of the decisionmakers. The consideration can also be a function of the politics of the situation. In some cases, such as the only treatment for an otherwise fatal condition, the cost-effectiveness result is not likely to make a difference in treatment decisions. This does not mean that economics will not be important at all. Decisionmakers and those requesting systematic reviews of evidence should carefully distinguish between not asking for any economic evidence and simply not asking for data to be gathered, summarized, and analyzed at the level of rigor of a systematic review.

Each of the three criteria mentioned above can be dichotomized for simplicity: high or low incremental cost, large or small incremental effect, and a high or low probability that the magnitude of the expenditure will affect the decision.

The magnitude of incremental costs and effects are quantitative measures. The issue of whether the magnitude of the expenditure will affect the decision is a subjective issue. The subjective issue can be guided by thinking about several issues. First, how local is the decision? The more local the decision, the greater the limits on resources and the more likely that decisionmakers will be cognizant of the resource limitations and be interested in cost data. Second, how many options exist for the target patient population? Is there only one option or are there multiple effective options? In cases with a single effective option, the magnitude of expenditures is likely to play a less important role in the decisionmaking process, although this may be changing. A national decision for a new biologic agent that would be the only effective treatment for a particular type of cancer would be unlikely to focus primarily on the magnitude of expenditures. In contrast, a decision at a community health center about another new medication for hyperlipidemia would likely be heavily influenced by the magnitude of expenditures. The assumption is that the community health center (particularly, since its board includes community representation) would be concerned about either a societal perspective, or the perspective of their patients who do not necessarily have full insurance.

We choose to ignore the situations in which an intervention is associated with a negative incremental cost and a positive incremental effect relative to the current best practice. In that case, the new alternative would be said to dominate the status quo. While there is no guarantee that the more effective and less expensive treatment option will be chosen, there is little economic question here. If it is unclear whether the new option is both more effective and less expensive, but this outcome is expected, then economic data alongside a systematic review can be very useful. However, if the cost differential is certain, there is little reason to collect economic data alongside a systematic review of the effectiveness. One example of a dominant technology is influenza vaccination for specific high risk target populations. In this case, economic data alongside a systematic review could be useful to direct policy, but that is only the case because of the need to demonstrate the favorable economic outcome alongside the clinical outcome. Another issue with one alternative that dominates another is the possibility of different interpretations regarding dominance when different time horizons are used. Time horizons are the time periods that are relevant to different decisionmakers; not every decisionmaker will care about the same amount of time. The savings for the dominant alternative may materialize as downstream financial savings many years in the future while the decisionmaker is more focused on short-term results. In that case, the decisionmaker may want to treat the assessment of the importance of cost data using the nondominant discussion below.

We also ignore the situation in which there is a positive incremental cost and a negative incremental effect of a new intervention. This would be dominated by the status quo. These types of interventions are never likely to be adopted, so there is little opportunity for change from the status quo.

Our primary focus is on situations in which a new treatment alternative is more effective and more expensive. We could address similar issues about situations in which new interventions are less expensive and less effective. However, in the United States, while such interventions may be cost-effective, they rarely get much attention.

Table 2 focuses on decisions about interventions or technologies that are more effective and more expensive than the status quo. The information presented is for making intuitive arguments based on relative costs. We do not claim to define the exact threshold for when a cost or an effect becomes “large” rather than small. The key is to interpret the results within the context of the decision at hand. When we use the terms cost and effect we are focusing on incremental costs and effects—how much more expensive than the status quo (assuming that we would be willing and able to continue to invest in the status quo) and how much more effective than the status quo. The most appropriate time for gathering data alongside a systematic review for effectiveness is when there is a question regarding the value of the treatment or intervention. This may occur regardless of how large the incremental effects are. It is also important to recall that the purpose of this document is to detail when to collect economic data alongside the effectiveness review and not to decide when to conduct an effectiveness review. That decision has already been made in the context of the discussion in this document.

Table 2 Criteria to guide when to ask for economic evidence in a systematic review

Expected Incremental Cost | Expected Incremental Effect | Will Economic Evidence Change Decision? | Priority for Asking for Economic Evidence
Low | Small | Low Probability | Low Priority
Low | Small | High Probability | Medium Priority
Low | Large | Low Probability | Very Low Priority
Low | Large | High Probability | Low Priority
High | Small | Low Probability | Medium Priority
High | Small | High Probability | High Priority
High | Large | Low Probability | Low Priority
High | Large | High Probability | Medium Priority

In deciding whether to ask for economic evidence alongside other evidence in a systematic review, we are focusing primarily on short-term costs and primarily budgetary (or financial) costs rather than economic opportunity costs. We have chosen to do this as many decisionmakers, despite the scientific recommendations about decisionmaking, focus on such costs rather than all long-term costs. However, this is a loose definition and may be adapted by specific decisionmakers. Some decisionmakers will be interested in focusing on all of society's opportunity costs while others will be focused only on budgetary financial costs. While most of the focus is on short-term effects, specific decisionmakers may focus on long-term present value. We are not trying to discourage following the scientific recommendation to consider societal long-term costs, but we are trying to offer pragmatic suggestions about how to gather useful economic data alongside a systematic evidence review.

Table 2 has two rows for which the result is relatively “obvious.” The first is the case of a low incremental cost, a large incremental beneficial effect, and a low probability of the economic evidence changing the decision. In that case, there is a low priority on economic data. Despite the low priority, a decisionmaker may want to know something about the supporting economic evidence. In that case, the evidence does not have to be gathered and analyzed with the precision and detail of a systematic review of evidence. In contrast, if the expected incremental costs are high, the expected incremental beneficial effect is small, and the economic evidence has a high probability of changing the decision, then it would be logical to ask for data gathered with the rigor of a systematic review of evidence.

In the other six boxes we offer some guidance, placing a high priority on the expected costs while paying attention to the probability of changing the policy decision. For example, if the incremental costs are low, the incremental effect is small and there is a low probability of changing the decision, it would less appropriate to ask for economic evidence treated with the rigor of a systematic review. In contrast, if the incremental costs are high, the incremental beneficial effect is small, and the probability of changing the decision is low, it might be a more appropriate but not absolutely necessary time to ask for economic evidence. It is a high priority to ask for a full review of economic evidence when expected incremental costs are high with a small incremental effect and a high probability of changing the decision. When expected incremental costs are low with a small incremental effect and a high probability of changing the decision, it may still be a medium priority to ask for a review of the economic evidence. Although low incremental costs with a large incremental effect and a low probability of changing the outcome suggests a very low priority for reviewing economic evidence, the priority also is low when the incremental costs are high with a large incremental effect and a low probability of changing the outcome. Finally, when the incremental cost is high and the incremental effect is large with a high probability of changing the decision, it may not be absolutely necessary to request a detailed review of economic evidence, but it seems reasonable to assign at least medium priority to including economic evidence in the review.

The analysis requiring economic data prior to the systematic review is somewhat complicated; the highest quality data may not be found until the review is conducted. To make a decision prior to the conduct of the systematic review, preferred sources of data would include prior reviews, surveillance data, and financial cost data, although they may be a subset of all data that will be used for analysis.

## Stakeholders—Who Is Interested in Economic Evaluation Data?

Health care policy and medical care decisionmaking potentially involve a large number of different parties or stakeholders. While the scientific recommendation is generally to perform an analysis from the societal perspective, very few stakeholders actually use this perspective when they are making a decision. The societal perspective, considering all benefits and all costs incurred, is appropriate for making optimal economic decisions for an entire economy. The difficulty is that a good outcome for the economy as a whole does not guarantee a favorable outcome for specific stakeholders, and some specific stakeholders (e.g., a private payer) should not be expected to consider the entire societal perspective. When the societal perspective suggests a positive outcome, but individual stakeholders are not convinced it is good for them, there is no obvious way to make transfers between stakeholders to facilitate turning the situation into a win-win situation for all concerned.

Stakeholders include governmental agencies. At the federal level, stakeholders include the Food and Drug Administration (FDA), the Centers for Medicare and Medicaid Services, and federally qualified community health centers. At the state level, stakeholders include health departments, and Medicaid administrators. Other stakeholders include private insurers, manufacturers, health care providers, health care facilities (such as hospitals, ambulatory surgery centers, group practices, etc.), employers, and patients and their families.

Most stakeholders will be worried about their own “bottom line.” Later, when we link data elements to specific decisionmaking contexts for specific stakeholders, this will be apparent. However, all stakeholders (even public and private insurers) should be interested in the perspective of the patient, the provider, and any relevant manufacturers because the patients and providers together determine the demand for care and the manufacturers are integral to determining the supply of specific types of care. It is critical to recognize that economic evidence that supports the adoption or nonadoption of a new technology or new intervention from one stakeholder's perspective will not necessarily support adoption or nonadoption from all perspectives. Ultimately, no matter what incentives are created by the insurers or other health care payers, unless the adoption or nonadoption of a new intervention or treatment makes economic and clinical sense to the providers, patients, facilities and relevant manufacturers, the new intervention or treatment will not be implemented successfully.

Employers have a role in the process by providing benefits that may include health insurance, which may be self-financed. In light of the health care reform bill passed in 2010, employers will continue to have a stake in and concern about issues related to the productivity of their workers and sick time. Employers also will continue to have a direct role in the insurance process.

Society is a perspective that is often used for analyses. This perspective is intended to capture all costs and all effects. This is a useful theoretical construct and helps to indicate when there is a potential gain in economic efficiency. This perspective does not, however, show specific stakeholders what they stand to gain or lose based on a particular implementation of a new treatment alternative or change in policy. Taking a societal perspective can help to emphasize long-term costs and benefits. Thus, it is useful to consider the stakeholders who make up society in addition to considering the effect on the entire economy. In many cases, multiple stakeholders will be interested, and the data that are located may have to be modified to be relevant to specific stakeholders. Even when using less than a societal perspective, it is important to realize that for accountability any stakeholder should be aware of how decisions will affect other perspectives. Economic theory suggests that decisionmakers generally only look at their own well being or profit when making decisions. Recognizing that terms like “payer” or “regulator” can refer to many different individuals and organizations, we summarize the stakeholders with the following terms.

- Regulator: In the United States, the FDA is not allowed to use economic data to determine whether a drug should be approved for use, although the FDA does evaluate the economic data that manufacturers intend to provide to consumers who may be interested in this evidence. In other countries, there may be other regulatory bodies that are interested in economic evidence. These may be interested in systematic reviews of effectiveness to determine whether to approve a new drug or device. The data on summary costs and unit prices would provide information for understanding the budgetary implications of the regulatory decision or could influence a decision if cost-effectiveness were part of the regulatory process. Other regulators (such as those in charge of certificate of need programs) are much more interested in economic data.
- Private Third-Party Payer: In the United States, this would primarily be private health insurance companies or other types of private insurance companies that pay for medical care expenditures such as car insurance companies. Employers may also be direct third-party payers if the employers are self-insured. Third-party payers use varying levels of managed care techniques. A small number of third-party payers are also providers (e.g., traditional staff model health maintenance organizations), and in this case the combined interests must be considered. In other countries, the list would be almost exactly the same. A systematic review of effectiveness would be of interest in deciding whether to cover a technology—making sure only to cover those that are effective or perhaps as effective as existing technologies. The data on summary costs and unit prices would help in understanding the budget impact and how to set reimbursement and coverage policy. A third-party payer's perspective diverges from society's perspective for a number of reasons, including the fact that many long-term benefits to society will not accrue to private third-party payers when enrollees switch payers ever three to five years. With respect to the term “private third-party payers,” it is also useful to note situations in which the employer is ultimately the payer and the insurer plays only an administrative role.
- Public Third-Party Payer: In the United States, the two largest third-party public payers are Medicare (a federal program with some variation in payment level by region of the country) and Medicaid (a federal state partnership program with much more variation). There are other public third-party payers but these are much smaller than either Medicare or Medicaid. The interest in systematic reviews of effectiveness and in the economic data is similar to those of a private third-party payer. There are many other government payers: the Department of Defense, the Department of Veterans Affairs, CHAMPUS, and the coverage for government employees. These would have their own interests although they are all part of the government perspective. The interests of the government when insuring its employees are likely to be similar to the interests of private third-party payers. However, the government does have different types of oversight to be concerned about as the expenditures on employees are a matter of public record and public discourse in ways that the expenditures for employees of private employers are not.
- Public Health Planner: This would include local, state, and federal agencies. At the local level, this would most likely be a health department. The same would be true at the state level. At the federal level, public health planning is done within the Centers for Disease Control and Prevention and the Health Resources and Services Administration within the Department of Health and Human Services. A public health planner would be interested in effectiveness to ensure that public resources are used for only the most effective interventions. Accompanying data on summary cost and unit prices would allow the planner to assess whether the new intervention fits within the available budget.
- Provider: This is not meant to be only physicians. This would include physicians, nurse practitioners, complementary and alternative care providers, and any individuals or groups of individuals who are part of the system of providing care. Providers are interested in their own well being and the interests of their patients. This is a key distinction from facilities which are listed below. Even providers driven by a profit motive would like to provide the most effective care. Their interest in data related to costs is most likely related to the expense of providing services rather than the expenditures necessary to use services.
- Facility: Facilities include hospitals, nursing homes, ambulatory surgery facilities, community health centers, and others. The key is that there are multiple individuals, and the decisionmaker's job is to make the best decision on behalf of the organization rather than on behalf of himself or herself. Facilities have interests similar to the providers.
- Employer: In the United States (which has consistently, although not always, had a relatively low unemployment rate), employers have a variety of interests in the health care system. Not all employers offer health insurance. Those who do are certainly interested in the health care system and changes in technology or interventions. Self-insured employers will experience financial costs directly. Employers who purchase insurance from a third-party payer are interested in new technologies and interventions because changes will affect the premium that must be paid and the incentives that will be offered to employees. Even outside the insurance issues, employers are interested in changes in technology and interventions because they affect workers' absenteeism and level of productivity when at work. Employers might have interests similar to payers. They also may be interested in the adoption or nonadoption of certain technologies or interventions within a workplace which would make their interests more similar to a facility or provider.
- Manufacturer: Manufacturers of pharmaceutical products and medical devices are interested in economic evidence that will determine the incentives for providers to prescribe and consumers to use the products of the manufacturers. Manufacturers are most likely to pursue effective products. The prices would help manufacturers to make appropriate profit maximizing decision. If the market would not bear a price that would be necessary to make a new product profitable, it will not be produced. There are many businesses in addition to the actual manufacturers of products who could be very interested in the economic data alongside systematic reviews of evidence of effectiveness.
- Patients/Families/Consumers: Patients are interested in economic evidence for their own and their families' decisionmaking purposes. Families are interested in economic evidence when they are required to make specific medical decisions on behalf of patients in their families, or when they have to make decisions about how to provide long-term care for family members. Finally, consumers in this case may refer to people who make decisions about the use of health care services outside of a doctor-patient relationship. Consumers want to use only effective interventions and are interested in the financial (out-of-pocket) and opportunity cost implications as they affect consumers' budgets and the value of consumers' insurance products.

We will not list society as a stakeholder because society is ultimately made up of all the other stakeholders and all economic evidence is of interest when an analyst is trying to present a societal perspective.

## Economic Components—What Economic Evidence Is of Interest?

The economic measures that are included cover a broad range of items that can be grouped into three categories.

- Demand for care
  ○ Time: The demand for care depends on the time required to travel to, wait for, receive, and return from receiving medical care. Time is valuable. These data could be found in a time and motion study, a cost-outcome analysis, or a study of the demand as a function of time.
  ○ Distance: The demand for care also is affected by distance, where distance is separate from the time required to receive medical care because the cost of traveling different distances will vary because of different public transit fares or different amounts of mileage costs in a personal car. These data are likely to be found in the same types of studies as time data because time and distance often are correlated.
  ○ Price of the innovation: A new technology or procedure will have a specific price attached to it that will affect the demand for the technology or innovation. The price may be the result of market equilibrium (e.g., rehabilitation services that are not covered by a third-party payer) or the result of incentives provided by a third-party payer. The price can change over time, but it is difficult to anticipate exactly how and when the price will change. These would likely have to be projected from existing data on other products.
  ○ Price sensitivity: Consumer demand will depend not only on the initial price but on how much the price is likely to change and the accompanying changes in the quantity demanded. The relationship between the percentage change in price and the percentage change in quantity is referred to by the term “elasticity.” Many empirical studies focus on elasticity.
  ○ Substitutes and complements: Patient demand will be determined not only by the monetary, time, and travel costs of the good but also by what other goods and services are available that may be substitutes for or complementary to the procedure or technology in question. In addition to studies focusing on own-price sensitivity, at least some studies also focus on cross-price sensitivity and could yield insight on what are substitutes and complements and how these will be affected by a new product.
  ○ Willingness to pay: This reflects the patient's valuation of a good or service. In contrast to markets that do not involve third-party payers, the willingness to pay for medical care does not correspond directly with demand and measures of consumer surplus as patients do not have to pay the entire cost of the treatment when they are insured. However, when conducting economic evaluations, particularly cost-benefit analyses, the willingness to pay is a key component of the analysis. Typically there are few studies of willingness to pay, although these studies are becoming more common as cost-benefit analysis is becoming at least somewhat more popular.
  ○ Absenteeism/Presenteeism: Absenteeism is time missed from work. This could lead to a loss of income. Even if a patient has sufficient sick leave not to lose income, there may still be a psychological loss of purpose. If the condition persists for a sufficient time, the patient will eventually lose his or her job. Presenteeism is a term used to reflect a lack of productivity compared with some optimum when the patient is at work while ill. This may bring a psychological cost to employees who believe that they should always be highly productive but is unlikely to result in an immediate loss of income. The avoidance of both absenteeism and presenteeism is a benefit of good health. The desire to achieve the benefits of good health leads to a derived demand for health care. Thus, absenteeism and presenteeism can be used as measures of burden in cost-effectiveness or cost-benefit analyses, and can be used to understand the derived demand for health care. The absenteeism and presenteeism associated with many conditions and treatments is being studied around the world.11
- Supply of care
  ○ Economies of scale: Suppliers of care and suppliers of the technology will be interested in whether there are opportunities to supply a product at a lower average cost as the quantity of production increases. Much research has been done to examine economies of scale in health care markets.
  ○ Changes in efficiency over time: Suppliers of care and suppliers of the technology will be interested in whether there is a learning curve that will be associated with greater efficiency in service provision over time. These types of data are interesting, but very few studies are done to compare efficiency over time.
  ○ Return on investment in innovation: Decisions on whether to adopt a new technology or implement a new procedure ultimately will be based on whether the return on investment will be higher than what could be achieved by other uses of the resources that are being invested. These data, particularly for an individual organization, are rarely found in the literature.
- Summary measures of equity and efficiency
  ○ Cost of illness: A measure of the expected lifetime costs of the onset of a condition.
  ○ Burden of disease: A measure of the costs (and possibly quality of life and potential years of life lost) attributable to a condition within a year.
  ○ Quality of life: A broad measure that is often, but not always, combined with costs in assessing the impact on a person's functioning and well-being.
  ○ Budget impact: A type of model that reflects only monetary outcomes—usually for a specific organization.
  ○ Incremental cost-effectiveness (cost-utility) ratio: An analysis comparing the extra costs with the extra value obtained from an intervention, procedure, or technology. Cost-utility analysis includes a particular valuation of quality of life.
  ○ Net-benefit: The result of a cost-benefit analysis in which all outcomes (including life and health) are valued in dollars.
  ○ Disparities: Various measures of differences in outcomes among subsets of a population. These may be driven by heterogeneous outcomes related to patient characteristics or to system characteristics. While most systematic evidence reviews are aimed at pharmaceuticals or other types of treatment for individual patients, it is also worth considering system-wide effects and interventions.

Table 3 summarizes the economic evidence elements of greatest interest to specific stakeholders in specific decision contexts—thus linking the who, what, why, and when questions addressed above. The stakeholders' considerations are not necessarily limited to what is in the boxes, but these are considered the most important. For example, a manufacturer faced with a reimbursement rate only needs supply-oriented data to indicate how much to produce to make a profit maximizing decision. When data are unavailable, a common practice is to rely on expert opinion or to attempt to find data on similar products in other markets. We will elaborate on Table 3 using the stakeholder as the organizing principle, thus discussing a stakeholder's interest in different decisionmaking contexts.

Table 3 Most critical data elements for specific stakeholders in specific decision contexts

| Stakeholders
Decision Contexts | Regulator^a^ | Private Third-Party Payer^b^ | Public Third-Party Payer^c^ | Public Health Planner^d^ | Health Care Professional^e^ | Health Care Facility^f^ | Employer | Manufacturer | Patient/Family/Consumer Groups | Research^g^
Approval & Monitoring | All Measures | Summary Measures & Demand | Summary Measures & Demand | All Measures | Summary Measures & Supply | All Measures | All Measures | Summary Measures & Supply | Summary Measures & Demand | Dictated by purpose of research, including the specific stake-holder and specific decision context of interest
Formulary Inclusion | X | Summary Measures & Demand | Summary Measures & Demand | X | Summary Measures & Demand | Summary Measures & Demand | Summary Measures & Demand | Summary Measures & Supply | Demand | Dictated by purpose of research, including the specific stake-holder and specific decision context of interest
Insurance Coverage | X | Summary Measures & Demand | Summary Measures & Demand | X | Summary Measures & Demand | Summary Measures & Demand | Summary Measures & Demand | Demand | Demand | Dictated by purpose of research, including the specific stake-holder and specific decision context of interest
Reimbursement Rate | X | Supply | Supply | X | Summary Measures & Supply | Summary Measures & Supply | X | Supply | X | Dictated by purpose of research, including the specific stake-holder and specific decision context of interest
Preferred Practice Guideline | X | X | X | X | Summary Measures | Summary Measures | Summary Measures | Summary Measures | Summary Measures | Dictated by purpose of research, including the specific stake-holder and specific decision context of interest
Technology or Nonadoption | X | X | X | Summary Measures | X | Summary Measures & Supply | Summary Measures | Summary Measures | Summary Measures | Dictated by purpose of research, including the specific stake-holder and specific decision context of interest
Clinical Management | X | X | X | X | Supply & Demand | All Measures | Demand | Demand | Demand | Dictated by purpose of research, including the specific stake-holder and specific decision context of interest

Note: X indicates that a particular decisionmaker is unlikely to have decisionmaking capacity for a particular decisionmaking context.

a In the United States this could be the Food and Drug Administration

b This includes fee-for-service plans and managed care organizations that may only pay for care or may hire health care providers

c This includes Medicare (Federal) and Medicaid (with State-level variation)

d An example would be a local public health department considering

e Includes physicians, nurse practitioners, health care educators and others

f Facilities can be both public and private organizations and include hospital, nursing homes, ambulatory surgery centers, and others

g Researchers and research funding agencies. The research interest will largely overlap with a specific perspective for which the research is funded.

Regulators' involvement is primarily at the point of approval and monitoring. At this stage, the regulators could have an interest in all economic measures. This could involve approval for any use at all, approval for a particular use, or approval of expansion of a facility or purchase of a new technology. For some decisions, there is not necessarily any economic input. For other decisions, economic inputs of all types might be useful.

Public and private third-party payers have similar interests. At the stages of approval and monitoring, formulary decisions, and insurance coverage, the third-party payers could take an interest in summary measures (to indicate how important the health problem is and how efficient a new treatment or monitoring system is) and demand figures. The demand figures assume that at the stage of formulary inclusion and insurance coverage, the third-party payer is a price taker. However, there is a separate decisionmaking context for a reimbursement level. At this stage, the third-party payer would be more interested in knowing about data on the supply of the product of service to make sure that reimbursement levels are set so that profits are not economically unreasonable.

Public health planners are most likely involved in two decision-making contexts—approval and monitoring and technology adoption or nonadoption. In the context of approval and monitoring, a public health planner could be interested in all economic measures. In the context of technology adoption or nonadoption, the key would be summary measures that indicate economic efficiency of the new treatment.

Health care professionals are likely to be interested in nearly all decisionmaking contexts—we have excluded technology adoption or nonadoption assuming that these decisions occur at a higher level. For clinical management, the most important factors are supply and demand factors. For preferred practice guidelines, the summary measures are of greatest interest. Summary measures of economic efficiency are also important to all the other decisionmaking contexts. Demand is more important for contexts that will dictate consumer incentives. Supply is likely more important in contexts that affect incentives for providers.

Other stakeholders would tend to be interested in economic data similar to those discussed so far. A key is that in some cases, self-interest of decisionmaking (as suggested by economic theory) would lead to more of a focus on a narrow range of measures—like consumers primarily being interested in demand and manufacturers being interested specifically in either supply or demand depending on the context.

While only a small number of stakeholders have been listed as being directly interested in cost-effectiveness, this requires some clarification. Many of the stakeholders are likely to be interested in whether a new treatment alternative is deemed to be cost-effective in comparison with other interventions. However, not all stakeholders will make their decisions primarily based on cost-effectiveness. Some stakeholders will make decisions based on other economic data about comparisons of the effectiveness of a new treatment with extant treatments and responses to changes in economic incentives.

## How Should the Economic Evaluation Be Conducted? Should the Economic Evaluation Be a Summary of Existing Evaluations or New Evaluations With Inputs Consistent With the Remainder of the Systematic Review?

In general, the preferred choice is to perform a new analysis (essentially redoing a state-of-the-art cost-effectiveness analysis) so that the inputs to the model are consistent with the results of the systematic review of evidence and the results are applicable to the question to which the systematic review is addressed. In such cases, a review will help to identify key parameters for the economic model, and reciprocally the new economic model will help to identify important issues for the review. However, this is not always feasible, and the many tradeoffs that exist will be discussed below. In addition to discussing a number of interesting tradeoffs, we will also discuss the options of conducting the economic evaluation alongside the systematic review or conducting the two sequentially.

Those commissioning and planning systematic reviews must consider several issues and tradeoffs when addressing the issue of whether to perform a new economic evaluation that is consistent with the findings from the systematic review or whether to simply review the economic data that exist. Of course, the first issue is the quality of existing economic studies. The tradeoffs include: the feasibility in terms of cost, time, and the need for expertise; the applicability of the existing literature to the question at hand; the internal and external validity of the results; the quality and credibility of the analyses; and the transparency of the analyses.

Performing an analysis de novo will, by definition, be more costly. To conduct a de novo analysis, all the steps that would have to be performed for a review of extant data will have to be performed anyway. With highly constrained financial resources, the argument for reviewing existing findings would be fairly strong. The possibility of performing a de novo analysis may be more feasible if it is possible to seek more resources for the economic evaluation after the main review of evidence is complete. Limited resources could also be an argument, then, for a sequential analysis.

Similar to the need for more money to conduct an analysis de novo, there is also a need for more time, and time may not always be available. In this case, the time available deadline will play a role in determining whether a sequential analysis would even be possible. If there is a fixed timeline for the completion of the project and that timeline is short, then a sequential analysis is not likely possible. On net, if there is a relatively long timeline, it would be preferred to perform a de novo analysis.

A review of extant studies could be completed without the need for expertise on performing economic evaluations. Rather, the research group would need only the expertise to interpret the results. The need for more expertise may be closely related to the need for more resources. The expertise may be unattainable if the expertise is not available internally for the decisionmaker or there are insufficient resources to hire an external collaborator.

Another consideration is whether the findings that exist in the literature are sufficiently applicable to the current decision situation. This is a standard research question. The existing literature may not be applicable to the decision at hand if it is old, if it deals with a different target population, comparison, or outcome, if it is from a different health care system, or if it is from efficacy rather than effectiveness studies. Cost-effectiveness should ideally be based on effectiveness studies so that the results come from situations that are as close to real world situations as possible. Differences in one of these criteria may leave the analyst concerned but willing to use extant results. However, differences in more than one of these criteria would suggest that the option of a review of existing literature would not be ideal.

The issues of internal and external validity and the quality of the studies are closely related (although there are certainly more criteria for the quality of the study than the internal and external validity). Higher quality extant results (based on any metric) will reduce the need for a de novo analysis.

The credibility of an analysis depends on both the quality and the certainty of the results. The goal is to maximize the credibility. Certainty is a function of both the statistical certainty of model parameters like effectiveness and the degree to which the qualitative nature of the results changes when parameters that do not have statistical uncertainty per se are varied across a reasonable range. In some cases, credibility would be maximized by using de novo results that are consistent with the review being conducted. In other cases, the credibility would be maximized by interpreting separate old results rather than combining multiple studies. This criterion does not always favor either de novo or a review of existing analyses.

The transparency is likely to be higher if existing results are presented and interpreted instead of being reviewed and synthesized in a de novo analysis. However, de novo analyses can also be transparent or nontransparent. The goal is to maximize transparency for the decisionmaker and for those affected by the decisions that result from the analysis. This criterion does not favor either the review or de novo in analysis in all cases.

When there are sufficient monetary resources in the short-run, or the sequential option is available, the time is not too short for a de novo analysis, and the expertise is available, a de novo analysis is a real possibility. Further, when the extant data are sufficiently applicable to the current decision situation, there is sufficient internal and external validity, and the extant studies are of sufficient quality, a simple review would be a real possibility. In this case, when both choices are realistic, several criteria can be used to guide the thinking of those commissioning and planning a review with the intent of including economic data.

- No pre-existing full economic evaluation relevant in the context of the systematic review;
- Substantial differences in the previous economic evaluation in terms of data used, methods and resulting findings;
- Substantial new evidence or evidence with decreased statistical variation regarding the cost or effectiveness since the most recent economic evaluation;
- Prior economic evaluations not based on the most up-to-date data on effectiveness rather than efficacy.

While the quality of the existing economic evidence is not always known prior to the conduct of the systematic review, another reason for conducting an original economic evaluation using results of the systematic review of evidence is if the quality of the prior evaluations was relatively poor. The criteria on which to judge the quality of studies is discussed in a separate document.12