# References

1 Neumann PJ, Palmer JA, Daniels N, Quigley K, Gold MR, Chao S. A strategic plan for integrating cost-effectiveness analysis into the US healthcare system. Am J Manag Care. 2008;14(4):185-8. [pmid: 18402510].
2 Eddy D. Reflections on science, judgment, and value in evidence-based decision making: a conversation with David Eddy by Sean R. Tunis. Health Aff (Millwood). 2007;26(4):w500-15. [pmid: 17580317].
3 Guyatt G, Oxman A, Kunz R, et al. Incorporating considerations of resources use into grading recommendations. BMJ: British Medical Journal. 2008;336(7654):1170-3.
4 American College of Physicians. Information on cost-effectiveness: an essential product of a national comparative effectiveness program. Ann Intern Med. 2008;148(12):956-61. [pmid: 18483128].
5 Garber A. A menu without prices. Ann Intern Med. 2008;148(12):964-6. [pmid: 18483127].
6 Wilensky G. Cost-effectiveness information: yes, it's important, but keep it separate, please!. Annals of Internal Medicine. 2008;148(12):967-8. [pmid: 18483126].
7 Berger ML, Teutsch S. Cost-effectiveness analysis: from science to application. Med Care. 2005;43(7 Suppl):49-53. [pmid: 16056009].
8 Aspinall S, Good C, Glassman P, Valentino M. The evolving use of cost-effectiveness analysis in formulary management within the Department of Veterans Affairs. Medical Care. 20-ii. 2005;43(7):II-26.
9 Tunis S, Carino TV, Williams RD II, Bach PB. Federal initiatives to support rapid learning about new technologies. Health Affairs. 2007;26(2):w140-9. [pmid: 17259196].
10 Tunis SR, Pearson SD. Coverage options for promising technologies: Medicare's ‘coverage with evidence development’. Health Aff (Millwood). 2006;25(5):1218-30. [pmid: 16966717].
11 Chatterji M, Tilley CJ. Sickness, absenteeism, presenteeism, and sick pay. Oxf Econ Pap. 2002;54:669-87.
12 Walker D, Wilson RF, Sharma R, Bridges J, Neissen L, Bass EB, Frick K. Best practices for conducting economic evaluations in health care: A systematic review of quality assessment tools. Methods Research Report. (Prepared by Johns Hopkins University Evidence-based Practice Center under contract No. 290-2007-1006-I). AHRQ Publication No. 12-EHC132-EF. Rockville, MD. Agency for Healthcare Research and Quality. August. 2012.
13 Walker D, Fox-Rushby JA. Economic evaluation of communicable disease interventions in developing countries: a critical review of the published literature. Health Econ. 2000;9(8):681-98. [pmid: 11137950].
14 Atkins D, Fink K, Slutsky J. Better information for better health care: the Evidence-based Practice Center program and the Agency for Healthcare Research and Quality. Ann Intern Med. 2005;142(12 Pt 2):1035-41. [pmid: 15968027].
15 Harris RP, Helfand M, Woolf SH, et al. Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med. 2001;20(3 Suppl):21-35. [pmid: 11306229].
16 Fox DM. Evidence of evidence-based health policy: the politics of systematic reviews in coverage decisions. Health Aff (Millwood). 2005;24(1):114-22. [pmid: 15647221].
17 Garber AM. Cost-effectiveness and evidence evaluation as criteria for coverage policy. Health Aff (Millwood). Suppl Web Exclusives. 2004:W4-284-96. [pmid: 15451997].
18 Higgins JPT, Green S, editors. Cochrane Handbook for Systematic Reviews of Interventions. Version 5.0.0 edition. The Cochrane Collection. 2008.
19 NHS Centre for Reviews and Dissemination. Undertaking systematic reviews of research on effectiveness: CRD's guidance for carrying out or commissioning reviews (2nd Edition). York. University of York: NHS Centre for Reviews and Dissemination. 2001. (CRD Report 4.
20 Juni P, Witschi A, Bloch R, Egger M. The hazards of scoring the quality of clinical trials for meta-analysis. JAMA. 1999;282(11):1054-60. [pmid: 10493204].
21 Au F, Prahardhi S, Shiell A. Reliability of two instruments for critical assessment of economic evaluations. Value Health. 2008;11(3):435-9. [pmid: 18489667].