# Peer Reviewers

Paul Barnett

Stanford University

Menlo Park, CA

Steve Gross

University of California, Berkeley

Berkeley, CA

Karen Kuntz

University of Minnesota

Minneapolis, MN

David Meltzer

University of Chicago

Chicago, IL

Ian Shemlit

University of Cambridge

Cambridge, UK