# Acknowledgments

The EPC thanks Ritu Sharma, Brandyn Lau, Dr. Hosne Begum, and Beth Barnett for their assistance with the preparation of this report, and Dr. William Lawrence for his valuable insight throughout the project.