# Discussion

The answers to the questions we addressed will provide critical guidance to those who are in a position to request systematic reviews that may include economic evidence and that may involve new economic evaluations consistent with the summary findings of effectiveness. Our results can help decisionmakers who have characterized the decisions they face to prioritize the economic evaluation data relative to clinical research data in the systematic review process. Stakeholders span the health and medical care system ranging from regulators to manufacturers, to providers, to patients. The decision contexts range from approval and monitoring to clinical management. In answering the question about when economic evaluation data should be collected and reviewed, we have dichotomized three criteria: the magnitude of the positive incremental cost, the magnitude of the positive incremental effect, and the magnitude of the perceived probability that the economic evidence will change the decision. In only one of eight combinations is high priority suggested: a small effect at a high cost with a high probability of influencing the result. In contrast, a very low priority is given to collecting such data when the incremental costs are low, the incremental effect is high, and the probability of impacting the decision is low. The situations in which it may be less important to gather data alongside systematic review are not necessarily situations in which all economic data are useless. Stakeholders will have to decide on what economic data are important in these situations as this particular report focuses only on what to collect alongside systematic reviews. A new full evaluation consistent with the results of a systematic review is most useful if there had been no previous full economic evaluation, if there were previous analyses with highly heterogeneous results, or if there were new cost or clinical data.

Systematic reviews may play a role in bringing economic data into the policy process.13 These reviews play a role in determining the comparative effectiveness of medical interventions and are critical for developing clinical practice guidelines, efficacy-based coverage decisions, and general health policy.14-17 The processes of searching for and summarizing studies illustrating clinical efficacy and effectiveness have been streamlined in the United States and elsewhere.18, 19 This report should help to do the same for economic data along with several other recent reports.20, 21 This report may also stimulate interest in assessing the extent to which published economic studies actually address the questions being raised in the systematic review of important clinical interventions. The circumstances of a health policy decision that are motivating a systematic review of evidence as viewed by the stakeholder requesting the systematic review may warrant that priority be given to collection, systematic review of, and analysis with primary economic data.