# Results

In the sections below, we present an overview of our included studies followed by results for each source of bias for which we found empirical evidence. Following a listing and description of the number of eligible studies (Figure 1), we summarize the characteristics of included studies (Table 3), including the approach used to minimize the potential effect of a bias that is evaluated in each study (i.e., blinding, allocation concealment), conditions examined and outcomes measured, the analysis design and data sources, and we note whether the study included stratified analyses or adjustments for other biases or other factors.

Figure 1 Disposition of articles

Figure 1 is a PRISMA tree that describes the steps and yield from each stage of this review. We identified 4844 abstracts of which we excluded 4679 during title and abstract review. We reviewed the full text for 165 articles and excluded 117. Reasons for exclusion included studies of medical tests (12), simulation studies (15), publication bias (5), other biases (18), other global biases (12), wrong design (52), and no original analysis (3). We included 38 studies (48 publications) in this review.

Table 3 Characteristics of included studies

Study | Bias Examined in Study | Conditions Evaluated Outcomes Reported/How measured | Analysis Design Data Source | Analysis Stratification by Disease, Condition, Trial Size Adjust for Other Biases or Other Factors
Schultz et al., 1995^22^ | Selection; - Allocation concealment; - Randomization; Attrition; - Exclusions after randomization; Detection/Performance; - Double-blinding (source not necessarily identified: could be identical/ active placebo) | Pregnancy, child birth, and early neonatal period Binary outcomes varied across studies; specific outcomes: NR | Level of analysis: MA (N=33 [250 RCTs]) Outcome: ROR Model: Logistic regression, adjusting for nesting in MA and other biases Data: Cochrane Pregnancy and Childbirth Database | Stratification: No, but assembled homogenous groups of interventions Adjusted for other 3 biases examined. Also: tx group, trial, variation across MAs
Juni et al.,1999^23^ | Selection; - Allocation concealment; Detection; - Assessor blinding; Attrition; - Handling of drop-outs and withdrawals (ITT) | Condition: General surgery Binary outcomes, thromboembolitic events (bleeding and DVT) | Level of analysis: RCT (N=17 included in 1 MA) Outcome: RRR Model: Fixed effects MA Data: MA by Nurmohamed et al. 24 | Stratification: No, all trials included same intervention and outcome No adjusting for other biases or other factors
Linde 1999^25^ | Selection; - Randomization (explicitly stated); - Allocation concealment; Detection/Performance; - Double-blinding (Patient and assessor); Attrition; - Complete followup | Conditions: Homeopathic interventions for tx or prevention Binary outcomes varied across studies; specific outcomes: NR | Level of analysis: RCT (N=89 included in 1 MA) Outcome: ROR Model: Multivariate Data: MEDLINE, EMBASE and CAM registries | Stratification: No Adjusted for other 3 biases examined
Moher et al., 1999,^26^ Moher et al., 1998^27^ | Selection; - Randomization; - Allocation concealment; Detection/Performance; - Double blinding (source not always identified: could be identical/active placebo); Attrition; - Adequate followup | Conditions: Digestive and circulatory diseases, mental health, stroke pregnancy and childbirth Binary outcomes varied across studies; specific outcomes: NR | Level of analysis: MA (N=11 selected randomly [127 RCTs]) Outcome: ROR Model: Logistic regression Data: Cochrane Database | Stratification: No No adjusting for other 3 biases Adjusting for: intervention effect, trial indicators, variation across MAs
Kjaergard, Villumsen and Gluud, 2001^28, 29^ | Selection; - Randomization; - Allocation concealment; Detection/Performance; - Double blinding (identical placebo tablets or similar); Attrition; - Adequate followup | Conditions: NR Binary outcomes: mortality, neonatal mortality, cesarean section, DVT, dropouts, endocervical cells, resumed smoking | Level of analysis: MA (N=14 [190 RCTs, 23 large, 167 small]) Outcome: ROR Model: Logistic regression Data: Cochrane Database and MEDLINE | Stratification: By small vs. large RCT ≥ 1,000 participants No adjusting for other 3 biases Adjusting for: intervention effect, trial indicators, variation across MA
Balk et al., 2002^30, 31^ | Selection; - Randomization; - Allocation concealment; Detection; - Assessor blinding; - Valid statistical methods; Performance; - Patient blinding; - Provider blinding; - Caregiver blinding; Detection/Performance; - Double blinding; Attrition; - Intention-to-treat analysis; - Dropouts recorded; Detection/Performance; - Double blinding (source not identified) | Outcomes: mortality in cardiovascular disease studies; varied in other clinical areas. If multiple outcomes, included those examined by the largest number of studies or those most clearly defined. | Level of analysis: MA (N=26 [256 RCTs]) Of these: Cardiovascular: (N=8 [93 RCTs]) Infectious disease: (N=6 [56 RCTs]) Pediatrics: N=5 [60 RCTs]) Surgery:(N=7 [67 RCTs]) Outcome: ROR Model: Baysian meta-regression with random effects, adjusting for clustering within MAs and variability across MAs Data: MEDLINE and Cochrane databases | Stratification: 4 disease areas Adjusting for other biases: No
Clifford et al., 2002^32^ | Selection; - Allocation concealment | Outcomes: Various conditions NS | Level of analysis: RCT (N=100) Outcome: OR Model: ANOVA Data: 1 year of issues of 5 selected high-impact medical journals | Stratification: direction of RCT outcome: (favored new intervention; favored conventional; neutral; unclear) Adjusting for other biases: Funding source
Sterne et al., 2002^16^ | Selection; - Allocation concealment; Detection/Performance; - Double-blinding (source not always identified: could be identical/ active placebo) | Same as Schulz et al., 1995^22^ | Level of analysis: MA (N=33 [250 RCTs]) Outcome: ROR Models: comparison of logistic regression, fixed and random-effects MA Data: Same as Schultz et al.22 | Stratification: No No adjusting for other biases Adjusting for variation across studies and MA differed by model type
Als-Nielsen et al., 2003^33^ | Detection/Performance; - Double-blinding (described as double blind) | Varied/mix of conditions across studies Binary outcomes varied across studies; specific outcomes: NR | Level of analysis: RCT (N=370 [25 MA]) Outcome: OR Model: logistic regression MA Data: Cochrane Database | Stratification: Disease area, and type of intervention Adjusting for other biases: Funding type
Egger et al., 2003^34, 35^ | Selection; - Allocation concealment; Detection/Performance; - Double-blinding (described as double blind or included assessor blinding) | Infectious diseases, neurology, obstetrics and gynecology, other Binary outcomes varied across studies; specific outcomes: NR | Level of analysis: MA Allocation concealment: (39 [304 RCTs]; Blinding: (45 [399 RCTs]) Outcome: ROR Model: Meta-regression Data: Cochrane Database; Health Technology Assessment and 8 medical journals that regularly publish SRs | Stratification: Yes, by Intervention: drug vs. nondrug, active vs. nonactive control, complementary vs. conventional medicine Adjusting for other biases: No
Chan et al., 2004^36^ | Reporting; - Selective outcome | Cardiology, obstetrics and gynecology, surgery, and pediatrics. Efficacy and harms (binary or continuous: NR), specific outcomes: NR | Level of analysis: RCT (N=48 RCTs [1,233 efficacy outcomes] and N=26 RCTs [169 harms outcomes]) Outcome: OR Model: Random-effects MA Data: PubMed, EMBASE and Cochrane Trials Register | Stratification: Efficacy, harms; fully or partially reported vs. qualitatively reported or unreported Adjusting for other biases: No
Chan et al., 2004^37^ | Reporting; - Selective outcome | Various conditions NS Efficacy and harms (binary, continuous or survival data), specific outcomes: NR | Level of analysis: RCT (N=50 [2,175 efficacy outcomes and 605 harms outcomes] Outcome: OR Model: Random-effects MA Data: Clinical studies approved by Scientific-Ethnical committees for Copenhagen and Frederiksberg, Denmark | Stratification: Efficacy, harms; fully or partially reported vs. qualitatively reported or unreported Adjusting for other biases: No
Kyzas et al., 2005^38^ | Detection/Performance; - Blinding (stated as blinded-level not specified); Reporting; - Outcome reporting | Head and neck squamous cell cancer Binary outcomes: all-cause mortality and lymph node status | Level of analysis: RCT (N=42) Outcome: RR Model: random and fixed effects MA Data: PubMed and EMBASE | Stratification: No Adjusting for other biases: No
Tierney et al., 2004^39^ | Attrition; - Intention-to-treat analysis | Cancers of the bladder, brain, lung, esophagus, ovary, lung, and soft tissue sarcoma Hazard of survival and recurrence | Level of analysis: MA and RCT level (N=14 MA & N=92 RCTs with at least one patient exclusion (21,905 patients) Outcome: HR Model: Fixed effects MA Data: SRs with MAs of patient-level RCT data addressing cancer therapies | Stratification: Disease condition Adjusting for other biases: No
Derry et al., 2006^40^ | Selection; - Randomization; Detection/Performance; - Double blinding (patient and assessor-practitioner [acupuncturist] could not be blinded) | Stroke, various painful conditions, nausea and vomiting, depression other conditions (insomnia, smoking cessation, weight loss, asthma) Binary measures: varied across studies | Level of analysis: RCT (N=35) Outcome: Relative risk Model: Random effects MA Data: PubMed, AMED, Cochrane Database | Stratification: sample size and control event rate by outcome (nausea, vomiting, antiemetic consumption Adjusting for other biases: Randomized and blinded combined
Furukawa et al., 2007^41^ | Reporting; - Selective outcome reporting | Conditions: Various conditions NS Measures: 2 binary and 2 continuous of greatest patient importance | Level of analysis: RCT (N=156) Outcome: OR and SMD Model: Linear regression Data: Cochrane database | Stratification: No Adjusting for other biases: No
Pildal et al., 2007^42^ | Selection; - Allocation concealment; Detection/Performance; - Double-blinding (source not necessarily identified: could be identical/ active placebo, could be patient and provider) | Varied conditions covered in 6 earlier meta-epi studies (Schulz et al., 1995,22 Moher et al., 1998,27 Kjaergard, Villumsen and Gluud, 2001,28 Egger et al., 2003,34 Balk et al., 2002,30 Als-Nielson, 2004^43^) Binary measures varied across studies | Level of analysis: MA Allocation concealment: (N=34 [283 RCTs]), Blinding: (N=20 [182 RCTs]) Outcome: ROR Model: Random effects meta regression Data: Cochrane Database, PubMed | Stratification: No Adjusting for other biases: No
Siersma et al., 2007^13^ | Selection; - Sequence generation; - Allocation concealment; Detection/Performance; - Double-blinding; Attrition; - Intention-to-treat | Conditions: Various NS Measures: Primary binary, varied across studies | Level of analysis: RCT (N=523 [48 MA]) Outcome: ROR Model: Logistic regression (with and without random effects), Weighted regression (with and without random effects) Data: Cochrane database | Stratification: No Adjusting for other biases: No
Fenwick et al., 2008^44^ | Selection; - Allocation concealment; Detection; - Assessor blinding | Periodontology Continuous measures: probing depth, and clinical or probing attachment level | Level of analysis: RCT (N=50, [allocation concealment, N=34; blinding, N=33]) Outcome: MD Model: Random effects meta-regression Data: Cochrane Database of SRs | Stratification: Outcomes of Probing depth, CAL/PAL Adjusting for other biases: No
Wood et al., 2008^45^ | Selection; - Allocation concealment; Detection/Performance; - Double-blinding (source not necessarily identified: could be identical/ active placebo, could be patient and provider) | Varied conditions covered in 3 earlier meta-epi studies (Schulz 1995,22 Kjaergard, Villumsen and Gluud, 2001,28 Egger et al., 2003^34^) Binary measures varied across studies-compared objectively vs. subjectively assessed outcomes | Level of analysis: MA Allocation concealment (N=102 [804 RCTs]) Blinding (N=76 [746 RCTs]) Outcome: ROR Model: Logistic regression and random effects meta regression Data: Cochrane Database, PubMed | Stratification: mortality vs. other outcomes; objective vs. subjective outcomes; drug vs. other interventions Adjusting for other biases: Yes
Hartling et al., 2009^46^, additional information :personal correspondence, Lisa Hartling, 2013 | Selection; - Randomization (sequence generation and allocation concealment); Detection/Performance; - Blinding | Conditions related to pediatric health Outcomes: Primary but NS | Level of analysis: RCT (N=163) Outcome: SMD Model: Multivariate meta-regression Data: Manuscripts resulting from Society for Pediatric Research meetings between 1992 and 1995 | Stratification: Outcome type (binary vs. continuous, objective vs. subjective) Adjusting for other biases: Study type (efficacy vs. equivalence), study design (crossover vs. factorial or parallel)
Inaba et al., 2009^47^ | Selection; - Randomization (sequence generation and allocation concealment); Detection; - Assessor blinding; Attrition; - Disclosure of withdrawals and dropouts | Acute myocardial infarction Binary outcomes: mortality, Continuous outcomes: impaired myocardial blush grade, ST-segment resolution | Level of analysis: RCT (N=25) Outcome: MD Model: DeSimonion and Laird random effects model, Meta-regression analysis (univariate and multivariate) Data: Cochrane Database, PubMed, hand searches | Stratification: study size Adjusting for other biases: single or multicenter design, type of devices used, study regions, presence of conflicts of interest
Nuesch et al., 2009^48, 49^ Nuesch et al., 2009^48, 49^ | Selection; - Allocation concealment; Performance; - Patient blinding; Attrition; - Excluding patients from the analysis | Pain from osteoarthritis of the knee or hip Nonbinary subjective outcomes from interventions (Patient reported pain) | Level of analysis: MA Concealment: (N=14 [158 trials]) Blinding: (N=10 [122 trials]) Outcome: SMD Model: Logistic regression Data: Cochrane, PubMed, EMBASE and CINAHL, last update: 11/2007 | Stratification: difference in treatment effect, small vs. large treatment benefits, high vs. low between-trial heterogeneity, nonpharmacologic vs. pharmacologic interventions, complementary vs. conventional medicine Adjusting for other biases: allocation concealment, intention-to-treat
van Tulder et al. 2009^50^ | Selection; - Allocation concealment; - Randomization; - Similarity of groups at baseline; Detection; - Assessor blinding; - Timing of outcome assessment; Performance; - Patient blinding; - Care provider blinding; - Effect of co-intervention differential compliance; Attrition; - Drop-out rate; - ITT | Nonspecific low back pain Continuous and binary measures: Pain, function, or similar improvement | Level of analysis: RCT (N=216) Outcome: SMD Model: Random effects meta-regression Data: Cochrane Library 2005: all Back Review Group reviews of nonsurgical tx for nonspecific low back pain. | Stratification: No Adjusting for other biases: No
Dwan et al., 2010^51^ | Reporting; - Selective outcome reporting | Acute asthma Outcome type: NS, Pulmonary function tests, including peak expiratory flow rate (PEFR) and forced expiratory volume in one second (FEV1), and hospital admission | Level of analysis: RCT (N=24) Outcome: RR Model: sensitivity analysis Sources: All RCTs included in the SR ‘Intravenous and nebulized magnesium sulfate for acute asthma’ | Stratification: Intervention and outcome Adjusting for other biases: No
Hamm et al, 2010,^52^ additional information: personal correspondence, Lisa Hartling, 2013 | Selection:; - Allocation concealment; - Randomization; Detection/Performance; - Double-blinding (source not identified); Attrition; - Drop-out rate; Reporting; - Selective outcome reporting | Unspecified Continuous and binary: Unspecified (primary trial outcome) | Level of analysis: RCT (N=236) Outcome: SMD when continuous & converted OR when binary Data: Pediatric RCTs published in Cochrane Registry in 2007 | Stratification: No Adjusting for other biases: No
Kirkham et al., 2010^53^ | Reporting; - Selective outcome reporting | Hepato-biliary, pregnancy and childbirth, neonatal, oral health, menstrual disorders and subfertility Outcomes not reported | Level of analysis: SR (N=283 [2486 RCTs]) Outcome: NR Model: Sensitivity analysis Data: Issue of the Cochrane library | Stratification: No Adjusting for other biases: No
Hartling et al., 2011^54^ | Selection; - Randomization (sequence generation and allocation concealment); Detection/Performance; - Blinding (source not identified); Attrition; - Incomplete data; Reporting; - Selective outcome reporting | Persistent asthma Continuous: Forced expiratory volume in 1 second (FEV_1_) | Level of analysis: RCT (N = 107) Outcome: MD Model: Random effects MA Data: RCTs included in a SR | Stratification: No Adjusting for other biases: No
Hempel et al., 2012 35, 2011^55^ | Selection; - Randomization (sequence generation and allocation concealment); Detection; - Assessor blinding; Performance; - Patient blinding; - Care provider blinding; - Similar co-interventions/ compliance/timing; Attrition; - Drop-out rate; - ITT | Variety of conditions including back pain, digestive diseases, circulatory diseases, mental health, stroke, and pregnancy and childbirth. Variety of continuous and categorical outcomes measured as absolute treatment effect sizes, standardized treatment effect sizes and odds ratios | Level of analysis: RCT (N=600) Outcome: SMD, ROR Models: Random and fixed effects MA Data: Four large datasets that included RCTs that had been used in a variety of earlier MAs | Stratification: size of the treatment effect, condition, type of outcome Adjusting for other biases: No
Herbison 2011^56, 57^ Herbison 2006^56-58^ | Selection; - Allocation concealment | Condition: Not limited by condition Outcome: Any binary outcome | Level of analysis: MA (N =65 [389 RCTs]) Outcome: ROR Model: Random effects meta-regression Data: Cochrane library | Stratification: No Adjusting for other biases: No
Liu, LaValley and Latham, 2011^59^ | Detection; - Assessor blinding; Attrition; - ITT | Not limited by condition Continuous measure of lower limb muscle strength | Level of analysis: RCT (N=73) Outcome: SMD Model: Random effects MA Data: RCTs included in a recently published SR | Stratification: No Adjusting for other biases: ITT
Hartling et al., 2012 24 | Selection; - Randomization; - Allocation concealment; Detection/Performance; - Double blinding; Reporting; - Selective outcome reporting; Attrition; - Incomplete data | Conditions: Varied across studies and included circulatory and respiratory health, nutrition, metabolism, and diabetes, musculoskeletal health and arthritis. Outcomes: Objective and subjective | Level of analysis: RCT (N=154) Outcomes: SMD Model: Logistic meta-regression Data: random sample from previous study by Hopewell et al (2010) | Stratification: Type of outcome (objective or subjective) Adjusting for other biases: No
Hrobjartsson et al., 2012 60 | Detection; - Assessor blinding | Wound/ulcer, fractured bone, angina pectoris, facial folds, other Binary, varied by study, mostly subjective, such as patient function | Level of analysis: RCT (N=21) Outcome: ROR Model: Random effects meta-analysis Data: PubMed, EMBASE, PsychINFO, Cochrane library, High Wire Press, Google Scholar | Stratification: clinical problem, whether study arms were same type of procedure Adjusting for other biases: Funding, whether blinding procedure considered effective, whether patients seen by one or two assessors
Mhaskar et al., 2012 61 | Reporting; - Methodological quality | Conditions: Cancer Outcomes: Survival | Level of analysis: RCT (N = 429) Outcome: Ratio of HR Model: Univariate Data: All NCI Cooperative Group trials between 1968 and 2006 with protocols and publications available with unique RCTs | Stratification: Publication vs. protocol plus publication Adjusting for other biases: No
Savovic et al., 2012 6; Savovic et al., 62; Savovic 2012 62 | Selection; - Allocation concealment; - Randomization; Detection/Performance; - Double-blinding (source not necessarily identified) | Pregnancy and childbirth, mental and behavioral, circulatory system, digestive system, other factors, respiratory system, Other ICD-10, unclassified All-cause mortality, other objective, objectively measured but potentially influenced by clinician judgment, subjective, mixture of subjective and objective | Level of analysis: MA (N=234 [1973 RCTs]) Allocation concealment: (N=88 [811 RCTs]) Randomization: (N=104 [911 RCTs]) Blinding: (N=60 [592 RCTs]) Outcomes: ROR Model: Bayesian hierarchical bias model (allows for random intervention effects (between trial heterogeneity) within MA. Data: 7 earlier published meta-epidemiological studies | Stratification: outcome grouping (mortality, other objective, subjective or mixed) Adjusting for other biases: other two biases being evaluated

Abbreviations: AMED = Allied and Complementary Medicine Database; CAL/PAL = clinical or probing attachment level; CAM = complementary and alternative medicine; DVT = deep vein thrombosis; FEV1 = forced expiratory volume in 1 second; HR = hazard ratio; ITT = intention-to-treat; MA = meta-analysis; MD = mean difference; N = number; NCT = National Cancer Institute; NR = not reported; NS = ; OR = odds ratio; PEFR = peak expiratory flow rate; RCT = randomized controlled trial; ROR = ratio of odds ratios; RR = risk ratio; RRR = ratio of risk ratios; SMD = standardized mean difference; SR = systematic review; tx = treatment.

We provide a more detailed description of each included study in two tables included in Appendix D. Data we present in appendix tables include inclusion and exclusion criteria, unit of analysis (meta-analysis or trial), and sources for locating trials (or meta-analyses) used as data for the analysis, the interventions, comparators, populations, clinical conditions and outcomes of trials included in studies, and adjustments to the analyses.

The results for each source of bias are discussed in the text, with outcomes from each study included in the evidence summarized in a corresponding table (Tables 4 through 14).

Table 4 Summary of allocation concealment risk of bias results by study

Study Identification | Results of Allocation Concealment Bias | Impact on Treatment Effect + Increase - Decrease = No Difference
Studies with Odds Ratios (OR) or Ratio of Odds Ratios (ROR) or Ratio of Relative Risks = (RRR)
Schulz et al., 1995^22^ | ROR = 0.70 (0.62 to 0.79)^a^/^b^ (p < 0.001) | + (U)^a^/^b^
Juni et al.,1999^23^ | RRR = 1.12 (0.76 to 1.65) ˆ (p = 0.58) | = (I)ˆ
Moher et al., 1998^26^ companion Moher et al., 1999^27^ | ROR = 1.11 (0.76 to 1.63)^c^ (p = Not reported) | = (I)^c^
Linde et al., 1999^25^ | ROR = 0.84 (0.60 to 1.18)^d^ (p = Not reported) | = (I)^d^
Kjaergard, et al. 2001^28, 29^ | Original | Original
Kjaergard, et al. 2001^28, 29^ | ROR = 0.60 (0.31 to 1.15)^e^ (p = 0.12) | = (I)^e^
Kjaergard, et al. 2001^28, 29^ | ROR = 0.48 (0.25 to 0.92)^f^ (p = 0.027) | + (I)^f^
Kjaergard, et al. 2001^28, 29^
Kjaergard, et al. 2001^28, 29^ | Revised | Revised
Kjaergard, et al. 2001^28, 29^ | ROR = 0.82 (0.31 to 0.995) | = (I)
Balk et al., 2002^30^ | Overall ROR = 1.05 (0.91 to 1.21) | Overall =
Balk et al., 2002^30^ | CV ROR = 1.14 (0.96 to 1.42) | CV = (I)
Balk et al., 2002^30^ | ID ROR = 0.97 (0.68 to 1.42) | ID = (I)
Balk et al., 2002^30^ | PA ROR = 0.90 (0.58 to 1.28) | PA = (I)
Balk et al., 2002^30^ | SX ROR = 0.73, (0.36 to 1.24) | SX = (I)
Sterne et al., 2002^16^ | ROR = 0.66 (0.55 to 0.78) p<0:001^j^ | + (I)^j^/^k^/^l^
Sterne et al., 2002^16^ | ROR = 0.67 (0.57 to 0.78) p<0:001^k^ | + (I)^j^/^k^/^l^
Sterne et al., 2002^16^ | ROR = 0.67 (0.61 to 0.82) p<0:001^l^ | + (I)^j^/^k^/^l^
Egger et al.,2003^34^ | ROR 0.79 (0.70 to 0.89) p <0.001 | + (I +U)
Egger et al.,2003^34^ | Active control yes ROR = 0.71 (0.56 to 0.90) | No statistical differences for active control or drug intervention.
Egger et al.,2003^34^ | Active Control no ROR = 0.84 (0.74 to 0.97) p > 0.05 | No statistical differences for active control or drug intervention.
Egger et al.,2003^34^ | | No statistical differences for active control or drug intervention.
Egger et al.,2003^34^ | Drug intervention ROR = 0.79 (0.69 to 0.91) | No statistical differences for active control or drug intervention.
Egger et al.,2003^34^ | Non-drug intervention ROR = 0.79 (0.62 to 1.00) p > 0.05 | No statistical differences for active control or drug intervention.
Pildal et al., 2007^42^ | ROR = 0.90 (95% CI: 0.81 to 1.01) p=0.08 | = (I + U)
Siersma et al., 2007 13 | ROR = 1.04 (0.90 to1.19)^f^ (p = Not reported) | = (I)^f, g^
Siersma et al., 2007 13 | ROR = 1.03 (0.90 to1.17)^g^ (p = Not reported) | = (I)^f, g^
Wood et al., 2008^45^ | Any outcome: ROR = 0.83 (0.74 to 0.93) (p^ToI^ N/A) | Any outcome: + (I + U)
Wood et al., 2008^45^ | Other outcomes: ROR = 0.76 (0.66 to 0.87) (p^ToI^ = 0.002) | Other outcomes: + (I + U)
Wood et al., 2008^45^ | All-cause mortality: ROR = 1.01 (0.90 to 1.14)
Wood et al., 2008^45^ | Other outcomes: ROR = 0.80 (0.73 to 0.87)*
Wood et al., 2008^45^
Wood et al., 2008^45^ | Subjective outcomes: ROR = 0.69 (0.59 to 0.82) (p^ToI^ = 0.009) | Subjective outcomes: +(I+U)
Wood et al., 2008^45^ | Objective outcomes: ROR = 0.91 (0.80 to 1.03)
Wood et al., 2008^45^ | Subjective outcomes: ROR = 0.75 (0.63 to 0.88)*
Herbison 2011^57^ Herbison 2006^56^ | All group comparison: | + (G4)
Herbison 2011^57^ Herbison 2006^56^ | G1: Reference (central randomization) | = (G2/G3/G5/G6)
Herbison 2011^57^ Herbison 2006^56^ | G2: ROR = 1.02 (0.85 to 1.22)
Herbison 2011^57^ Herbison 2006^56^ | G3: ROR = 0.87 (0.76 to 1.00)
Herbison 2011^57^ Herbison 2006^56^ | G4: ROR = 0.86 (0.78 to 0.96)
Herbison 2011^57^ Herbison 2006^56^ | G5: ROR = 0.76 (0.66 to 1.15)
Herbison 2011^57^ Herbison 2006^56^ | G6: ROR = 0.89 (0.70 to 1.15)
Herbison 2011^57^ Herbison 2006^56^
Herbison 2011^57^ Herbison 2006^56^ | Two group comparison:
Herbison 2011^57^ Herbison 2006^56^ | ROR = 0.91 (0.83 to 0.99) | + (I + U)
Hempel et al., 2011^43, 70^ | Dataset 3: Jadad and Schultz
Hempel et al., 2011^43, 70^ | Schulz: concealment: ROR = 0.72 (0.46, 1.13)^m^ | = (I + (U)^m^
Hempel et al., 2011^43, 70^ | Schulz: concealment: ROR = 0.77 (0.61, 0.97)^n^ (p<0.05) | + (I + (U)^n^
Hempel et al., 2011^43, 70^
Hempel et al., 2011^43, 70^ | Dataset 4: Heterogeneity set
Hempel et al., 2011^43, 70^ | CBRG: ROR = 0.89 (0.73, 1.09) | = (I + (U)
Hempel et al., 2011^43, 70^ | CBRG: ROR = 0.89 (0.66, 1.18) corrected for clustering | = (I + (U)
Savovic et al., 2012^12, 62, 68^ | All outcomes = ROR 0.89 (0.81 to 0.99)^o^ | All outcomes + (I)^l^
Savovic et al., 2012^12, 62, 68^ | -> Increase in BW trial SD = 0.06 and MA SD = 0.05 | All outcomes + (I)^l^
Savovic et al., 2012^12, 62, 68^ | Mortality outcomes = ROR 1.03 (0.82 to 1.31^o^ | Mortality = (I)^l^
Savovic et al., 2012^12, 62, 68^ | -> Increase in BW trial SD = 0.07 and MA SD = 0.07 | Mortality = (I)^l^
Savovic et al., 2012^12, 62, 68^ | Other objective outcomes = 0.92 (0.76 to 1.12)^o^ | Objective = (I)^l^
Savovic et al., 2012^12, 62, 68^ | -> Increase in BW trial SD = 0.06 and MA SD = 0.06 | Objective = (I)^l^
Savovic et al., 2012^12, 62, 68^ | Subjective or mixed = 0.82 (0.70 to 0.94)^o^ | Subjective +(I)^l^
Savovic et al., 2012^12, 62, 68^ | -> Increase in BW trial SD = 0.08 and MA SD = 0.08 | Subjective +(I)^l^
Mhaskar et al., 2012^61^ | Publication: RHR = 0.94 (0.89, 0.99) | Publication: + (I)
Mhaskar et al., 2012^61^ | Protocol plus publication: RHR = 0.95 (0.87, 1.04) | Protocol +(I)
Studies With Mean Differences in Treatment Effect (MD), Standardized Mean Difference in Treatment Effect (SMD), Standardized Mean Effect Size (SMES) or Relative Risk (RR)
Fenwick et al., 2008^44^ | Outcome of probing depth: adequate vs. | Probing Depth:
Fenwick et al., 2008^44^ | MD = 0.22 (-0.58 to 1.03) p=0.59 (unclear) | Both: =( I + U)
Fenwick et al., 2008^44^ | MD = 0.60 (-1.70 to 1.89) p=0.37 (inadequate) | Both: =( I + U)
Fenwick et al., 2008^44^ | MD = 0.25 (-0.53 to 1.03) p=0.53 (unclear or inadequate) | Both: =( I + U)
Fenwick et al., 2008^44^
Fenwick et al., 2008^44^ | Outcome of clinical or probing attachment level (CAL/PAL): adequate vs. | CAL/PAL:
Fenwick et al., 2008^44^ | MD = 0.05 (-0.95 to 1.06) p=0.92 (unclear) | Both: = (I + U)
Fenwick et al., 2008^44^ | MD = -0.09 (-2.0 to 1.08) p=0.93 (inadequate) | Both: = (I + U)
Fenwick et al., 2008^44^ | MD = 0.10 (-1.01 to 1.04) p=0.98 (unclear or inadquate) | Both: = (I + U)
Fenwick et al., 2008^44^
Fenwick et al., 2008^44^ | (Positive MD in treatment effect indicates a tendency for a poorer quality study to obtain a larger treatment effect while a negative MD indicates a good quality studies obtain a greater treatment effect.)
Nuesch et al., 2009^48^ Nuesch et al., 2009^49^ | Adequate vs. not: (negative SMD indicates that trials with adequate concealment show a less beneficial effect)
Nuesch et al., 2009^48^ Nuesch et al., 2009^49^ | Overall SMD = -0.15 (95% CI, -0.31 to 0.02) | Overall: = (I + U)
Nuesch et al., 2009^48^ Nuesch et al., 2009^49^ | Large vs. small treatment benefit: SMD = -0.79 (95% CI, -1.02 to -0.50) (p^ToI^ = <0.001) | Large vs. small treatment benefit + (I+U)
Nuesch et al., 2009^48^ Nuesch et al., 2009^49^ | Drug vs. nondrug: SMD = -0.24 (95% CI, -0.53 to 0.04) (p^ToI^ = 0.26)
Nuesch et al., 2009^48^ Nuesch et al., 2009^49^ | Complementary vs. conventional: SMD = -0.52 (95% CI, -0.93 to -0.10) (p^ToI^ = 0.019 ) | Complimentary vs. conventional + (I + U)
Hempel et al., 2011^70^ | Dataset 1 (Back Pain):
Hempel et al., 2011^70^ | Allocation concealment: SMD= -0.08 (-0.23 to 0.07) | = (I + U)
Hempel et al., 2011^70^ | Dataset 2 (EPC set):
Hempel et al., 2011^70^ | Allocation concealment: SMD = -0.05 (-0.22 to 0.11)
van Tulder et al., 2009^50^ | SMD = -0.08 (-0.23, 0.07) (- value indicates that adequate concealment (higher quality) shows smaller effect) | = (I)
Hamm et al, 2010,^52^ | High risk of bias: SMD = 0.25 (-0.04 to 0.53) | =
Hamm et al, 2010,^52^ | Unclear risk of bias: SMD = 0.39 (0.28 to -0.50) | =
Hamm et al, 2010,^52^ | Low risk of bias: SMD = 0.38 (0.20 to -0.57) | =
Hamm et al, 2010,^52^ | (CIs overlap with each other. High risk of bias had smaller SMD than low risk of bias.)
Hartling et al., 2009^46^ | In comparison to adequate concealment, inadequate (p < 0.678) and unclear concealment (p < 0.480) results were not significantly different | =
Hartling, 2011^54^ | Forced expiratory volume: High/unclear RoB vs. low RoB: MD = 0.05 (-0.03 to 0.12) | = (H + I)
Hartling, 2011^54^ | Symptom-free days: High/unclear RoB vs. low RoB: MD = 0.55 (-4.48 to 5.59) | = (H + I)
Hartling, 2011^54^
Hartling, 2011^54^ | High RoB vs. unclear and low RoB: MD Not estimable
Hartling, 2011^54^ | High RoB vs. unclear and low RoB: MD Not estimable
Hartling et al., 2012^24^ | High risk of bias: SMES = - 0.38 (-0.29 to 1.05) | =
Hartling et al., 2012^24^ | Unclear risk of bias: SMES = 0.77 (0.65 to 0.88) | +
Hartling et al., 2012^24^ | Low risk of bias: SMES = 0.49 (0.30 to 0.68) | +
Hartling et al., 2012^24^ | Overall meta-regression p value = 0.10
Hartling et al., 2012^24^
Hartling et al., 2012^24^ | Stratified analysis: For allocation concealment, objective outcomes had higher RoB than subjective outcomes (p = 0.007).
Inaba et al., 2009^47^ | Mortality | Mortality: = (U)
Inaba et al., 2009^47^ | Unclear randomization RR = 1.1 (0.62 to 1.99) | Mortality: = (U)
Inaba et al., 2009^47^ | Yes randomization RR = 0.66 (0.46 to 0.95) | Mortality: = (U)
Inaba et al., 2009^47^
Inaba et al., 2009^47^ | Incomplete ST resolution | Incomplete ST: = (U)
Inaba et al., 2009^47^ | Unclear randomization RR = 0.67 (0.52 to 0.86); | Incomplete ST: = (U)
Inaba et al., 2009^47^ | Yes randomization RR = 0.83 (0.73 to 0.93) | Incomplete ST: = (U)
Inaba et al., 2009^47^
Inaba et al., 2009^47^ | Impaired Myocardial Blush Grade | Myocardial Blush: = (U)
Inaba et al., 2009^47^ | Unclear randomization RR = 1.1 (0.62 to1.99); | Myocardial Blush: = (U)
Inaba et al., 2009^47^ | Yes randomization RR = 0.66 (0.46 to 0.95) | Myocardial Blush: = (U)
Studies with Other Metrics for Showing Impact of Allocation Concealment: Odds Ratio (OR) and Relative Risk (RR)
Clifford et al., 2002^32^ | Funding not for profit: OR = 0.55 (0.21 to 1.42) | Not for profit protective
Clifford et al., 2002^32^ | Funding mixed sources: OR = 1.35 (0.46 to 3.98)
Clifford et al., 2002^32^
Clifford et al., 2002^32^ | OR suggest that not for profit funding is protective against unclear rating of allocation concealment.
Derry et al., 2006^40^ | Nausea: RR = 0.73 (0.57 to 0.93) | N/A
Derry et al., 2006^40^ | Vomiting: RR = 0.71 (0.56 to 0.91)
Derry et al., 2006^40^ | Antiemetic consumption: RR = 0.79 (0.61 to 1.02)

Notes: (+) = exaggerated impact from bias; (=) = no significant effect from bias, no significant difference between groups; (-) = reduced impact from bias, magnitude is decreased; (U) = relative to unclear allocation concealment; (I) = relative to inadequate allocation concealment

(G1) Trials that used some form of central randomization that clearly should hide the allocation (e.g., remote telephone service or randomization by a pharmacy).

(G2) Trials that used sealed envelopes with security enhancement (e.g., opaque and numbered); “Inadequate or unclear concealment” included.

(G3) Trials that used sealed envelopes without further details.

(G4) Trials that were reported as randomized without details, and also “double-blind.”

(G5) Trials that simply said they were randomized with no further details.

(G6) Trials where the allocation was clearly not hidden (e.g., based on an open list, odd/even days of the week, participant's birth date, team member on duty at enrollment).

a Adjusting for sequence generation, blinding, and post allocation exclusions

b Excluded trials with inadequate concealment and compared with trials with unclear concealment

ˆ Univariate analysis

c Allowing for summary Odds Ratio (OR) to vary simultaneously according to the components (i.e. component by treatment interactions)

d Adjusting for allocation concealment, blinding, post allocation exclusions and intent to treat.

e Large vs small trials with adequate versus inadequate trials.

f small trials with adequate versus inadequate trials

g Logistic regression with random effect

h Weighted regression with random effect

j Logistic regression model

k meta-analytic approach, within meta-analysis differences estimated using logistic regression

l meta-analytic approach, within meta-analysis differences estimated using random effects meta- regression

m random effects model

n fixed effects model

o adjusted for other biases

ToI p value of test of interaction

Abbreviations: CBRG = Cochrane Back Review Group; CI = confidence interval; EPC = Evidence-based Practice Center; ID = infectious disease; MA = meta-analysis; N/A = not available; OR = odds ratio; PA = pediatrics; RHR = ratio of hazard ratio; RoB = risk of bias; ROR = ratio of odds ratio; RR = risk ratio; RRR = ratio of risk ratio; SMES = standardized mean effect size; SD = standard deviation; SX = surgery.

Table 5 Summary of sequence generation risk of bias results by study

Study Identification | Results of Sequence Generation Bias | Impact on Treatment Effect* + Increase - Decrease = No Difference
Studies with results measured through Odds Ratios (OR), Ratio of Odds Ratios (ROR), Ratio of Hazard Ratios (RHR) or Ratio of Relative Risks (RRR)
Schulz et al., 1995^22^ | ROR = 0.95 (0.81 to 1.12)^a^ (p = 0.58) | = (U)^a^
Schulz et al., 1995^22^ | ROR = 0.75 (0.55, 1.02)^b^ (p <0.07) | = (A vs. ID AC)^b^
Moher et al., 1998/Moher et al., 1999^26, 27^ | ROR = 0.89 (0.67 to 1.20)^c^ (p = Not reported) | = (I)^c^
Linde et al., 1999^25^ | ROR = 0.64 (0.43 to 0.94)^d^ (p = Not reported) | + (I)^d^
Kjaergard, et al. 2001^28, 29^ | Original | Original
Kjaergard, et al. 2001^28, 29^ | ROR = 0.49 (0.30 to 0.81)^e^ p < 0.001) | + (I)^e^
Kjaergard, et al. 2001^28, 29^ | ROR = 0.52 (0.28 to 0.93)^f^ ( p = 0.029) | + (I)^f^
Kjaergard, et al. 2001^28, 29^
Kjaergard, et al. 2001^28, 29^ | Revised | Revised
Kjaergard, et al. 2001^28, 29^ | ROR = 0.95 (0.86 to 1.04) | = (I)
Balk et al., 2002^30^ | Overall ROR = 1.01 (0.85 to 1.18) (p not reported) | Overall =(I)
Balk et al., 2002^30^ | CV ROR = 1.14 (0.91 to 1.49) (p not reported) | CV = (I)
Balk et al., 2002^30^ | ID ROR = 0.93 (0.58 to 1.64) (p not reported) | ID = (I)
Balk et al., 2002^30^ | PA ROR = 0.88 (0.49 to 1.51) (p not reported) | PA = (I)
Balk et al., 2002^30^ | SX ROR = N/A | SX N/A
Siersma et al., 2007^13^ | ROR = 0.87 (0.74 to 1.01)^g^ | = (I)^g,h^
Siersma et al., 2007^13^ | ROR = 0.85 (0.72 to 1.01)^h^ | = (I)^g,h^
Hempel et al., 2011^35, 55^ | Dataset 3: Jadad and Schultz:
Hempel et al., 2011^35, 55^ | Jadad: randomization: ROR = 0.95 (0.62, 1.44)^j^ | Jadad = (I)^j,k^
Hempel et al., 2011^35, 55^ | Jadad: randomization: ROR = 0.88 (0.70, 1.09)^k^ | Jadad = (I)^j,k^
Hempel et al., 2011^35, 55^
Hempel et al., 2011^35, 55^ | Schulz: sequence: ROR = 1.01 (0.66, 1.56)^j^ | Schultz = (I)^k^
Hempel et al., 2011^35, 55^ | Schulz: sequence: ROR = 0.92 (0.74, 1.15)^k^ | Schultz = (I)^k^
Hempel et al., 2011^35, 55^
Hempel et al., 2011^35, 55^ | Dataset 4: Heterogeneity set
Hempel et al., 2011^35, 55^ | CBRG: ROR = 1.18 (0.94, 1.49) | = (I)
Hempel et al., 2011^35, 55^ | CBRG: ROR = 1.18 (0.83, 1.67) corrected for clustering | = (I)
Savovic et al., 2012^12, 62, 68^ | All outcomes: ROR=0.90 (0.82 to 0.99)^l^ | All outcomes + (I)^l^
Savovic et al., 2012^12, 62, 68^ | -> Increase in between trial SD = 0.06/MA SD =0.05 | All outcomes + (I)^l^
Savovic et al., 2012^12, 62, 68^ | Mortality outcomes ROR=0.86 (0.69 to 1.06)^l^ | Mortality =(I)^l^
Savovic et al., 2012^12, 62, 68^ | -> Increase in between trial SD=0.08/ MA SD =0.06 | Mortality =(I)^l^
Savovic et al., 2012^12, 62, 68^ | Other objective outcomes: ROR= 1.00 (0.84 to1.20)^l^ | Objective =(I)^l^
Savovic et al., 2012^12, 62, 68^ | -> Increase in between trial SD = 0.07/MA SD = 0.07 | Objective =(I)^l^
Savovic et al., 2012^12, 62, 68^ | Subjective/ mixed outcome: ROR=0.88 (0.76 to 1.00)^l^ | Subjective =(I)^l^
Savovic et al., 2012^12, 62, 68^ | -> Increase in between trial SD = 0.05 and MA SD = 0.06 | Subjective =(I)^l^
Mhaskar et al., 2012^61^ | Publication: RHR =1.01 (0.96, 1.05) | Publication: =
Mhaskar et al., 2012^61^ | Protocol plus publication: RHR = 1.00 (0.96, 1.05) | Protocol: =
Studies with Results Measured through: Mean Difference (MD) or Standardized Mean Difference (SMD) in treatment effect, or Standardized Mean Effect Size (SMES)
Hempel et al., 2011^55^ | Dataset 1 (Back Pain): | = (I)
Hempel et al., 2011^55^ | Randomization adequate vs. not: SMD = 0.02 (-0.12, 0.16) | = (I)
Hempel et al., 2011^55^
Hempel et al., 2011^55^ | Dataset 2 (EPC reports): | = (I)
Hempel et al., 2011^55^ | Randomization adequate vs not: SMD = 0.01 (-0.15, 0.17) | = (I)
van Tulder et al., 2009^50^ | SMD = 0.02 (-0.12, 0.16) | = (I)
Hamm et al, 2010,^52^ | SMES = 0.23 (0.07 to 0.39) High RoB | -(high vs. low)
Hamm et al, 2010,^52^ | SMES = 0.45 (0.30 to 0.60) Unclear RoB | -(high vs. low)
Hamm et al, 2010,^52^ | SMES = 0.34 (0.21to 0.46) Low RoB | -(high vs. low)
Hartling et al., 2009^46^ | SMD: Inadequate vs. adequate (p < 0.560) | = (I)
Hartling et al., 2009^46^ | SMD:Unclear vs. adequate (p < 0.262) | = (U)
Hartling et al., 2011^54^ | Forced expiratory volume: High or unclear vs. low: MD = -0.01 (-0.04 to 0.03) | = (I + U)
Hartling et al., 2011^54^ | Symptom free days: High or unclear vs. low: MD = 1.71 (-4.11 to 7.54) | = (I + U)
Hartling et al., 2011^54^ | Forced expiratory volume: High vs. Unclear or low: not estimable
Hartling et al., 2012^24^ | High bias: SMES = 0.86 (-0.35, 2.06)
Hartling et al., 2012^24^ | Unclear bias: SMES = 0.86 (0.68, 1.04)
Hartling et al., 2012^24^ | Low bias: SMES = 0.57 (0.47, 0.68)
Hartling et al., 2012^24^ | Overall meta-regression: p value = 0.10 | =
Hartling et al., 2012^24^ | Stratified analysis: For sequence generation, objective outcomes had greater bias than subjective outcomes (p=0.01).

Notes: (+) = exaggerated odds ratio from bias; (=) = no significant effect from bias; (-) = reduced odds ratio from bias; (U) = relative to unclear rating; (I) = relative to inadequate rating

a Adjusting for allocation concealment, blinding, and post allocation exclusions.

b Estimate based on trials stratified by adequate versus inadequate allocation concealment

c Allowing for summary odds ratio (OR) to vary simultaneously according to the components (i.e., component by treatment interactions)

d Adjusting for allocation concealment, blinding, post allocation exclusions and intention-to-treat.

e Large versus small trials with adequate versus inadequate trials

f Small trials with adequate versus inadequate trials

g Logistic regression with random effect

h Weighted regression with random effect

i Adjusting for blinding

j Random effects model

k Fixed effects model

l Adjusted for other biases

Abbreviations: CBRG = Cochrane Back Review Group; CV = cardiovascular disease; RoB = risk of bias; EPC = Evidence-based Practice Center; ID = infectious disease; MA = meta-analysis; N/A = not applicable; OR = odds ratio; PA = pediatrics; RHR = ratio of hazard ratios; ROR = ratio of odds ratio; RRR = ratio of relative risks; SD = standard deviation; SMES = standardized mean effect size; SX = surgery.

Table 6 Summary of confounding results by study

Study Identification | Allocation Concealment: Results of Bias | Effect^a^
Balk et al., 2002^30^ | Overall ROR: 0.96 (0.79 – 1.23) | =
Balk et al., 2002^30^ | Infectious disease ROR: 0.94 (0.60 – 1.49) | =
Balk et al., 2002^30^ | Pediatrics ROR: 0.96 (0.50-1.65) | =
Balk et al., 2002^30^ | Surgery ROR: 1.20 (0.76 – 1.72) | =
van Tulder et al., 2009^50^ | SMD: -0.10 (-0.24, 0.05) | =

a +: exaggerated odds ratio from bias; =: no significant effect from bias; -: reduced odds ratio from bias

Abbreviations: ROR = ratio of odds ratio; SMD = standardized mean difference.

Table 7 Summary of compliance results by study

Study Identification | Acceptable Compliance: Results of Bias | Effect^a^
van Tulder et al., 2009^50^ | ROR: -0.01 (-0.15, 0.14) | =
Hempel et al., 2011^74,b^ | SMD for dataset 2 (EPC reports): 0.02 (-0.12, 0.17) | =
Hempel et al., 2011^74,b^ | ROR for dataset 3 (“pro-bias”): 0.72 (0.59, 0.88) | +
Hempel et al., 2011^74,b^ | ROR for dataset 4 (“heterogeneity”): 1.12 (0.89, 1.41) | =

a +: exaggerated odds ratio from bias; =: no significant effect from bias; -: reduced odds ratio from bias.

b This row does not repeat results from dataset 1 because they appear in the row for van Tulder.

Abbreviations: EPC = Evidence-based Practice Center; ROR = ratio of odds ratio; SMD = standardized mean difference.

Table 8 Summary of cointerventions results by study

Study Identification | Similar Cointerventions: Results of Bias | Effect^a^
Van Tulder et al., 2009^50^ | SMD: -0.09 (-0.23, 0.05) | =
Hempel et al., 2011^74,b^ | SMD for dataset 2 (EPC reports): 0.05 (-0.15, 0.28) | =
Hempel et al., 2011^74,b^ | ROR for dataset 3 (“pro-bias”): 1.50 (1.22, 1.85) | -
Hempel et al., 2011^74,b^ | ROR for dataset 4 (“heterogeneity”): 0.85 (0.69, 1.03) | =

a +: exaggerated odds ratio from bias; =: no significant effect from bias; -: reduced odds ratio from bias

b This row does not repeat results from dataset 1 because they appear in the row for van Tulder.

Abbreviations: EPC = Evidence-based Practice Center; ROR = ratio of odds ratio; SMD = standardized mean difference.

Table 9 Summary of patient and/or provider blinding risk of performance bias results by study

Study Identification | Patient and/or Provider Blinding: Results of Bias | Effect^a^
Balk et al., 2002^30^ | Patients blinded vs. not:
Balk et al., 2002^30^ | - Overall: ROR = 0.95 (0.70 to 1.13) | =
Balk et al., 2002^30^ | - Cardiovascular disease: ROR = 1.08 (0.86 to 1.38) | =
Balk et al., 2002^30^ | - Infectious disease: ROR = 0.70 (0.46 to 1.11) | =
Balk et al., 2002^30^ | - Pediatrics: ROR = 0.79 (0.39 to 1.19) | =
Balk et al., 2002^30^ | Caregivers blinded vs. not:
Balk et al., 2002^30^ | - Overall: ROR = 0.98 (0.75 to 1.20) | =
Balk et al., 2002^30^ | - Cardiovascular disease: ROR = 1.09 (0.91 to 1.29) | =
Balk et al., 2002^30^ | - Infectious disease: ROR = 0.62 (0.43 to 0.91) | +
Balk et al., 2002^30^ | - Pediatrics: ROR = 1.13 (0.73 to 1.84) | =
Nuesch et al., 2009^48^ | Patients blinded vs. not:
Nuesch et al., 2009^48^ | - SMD = -0.15 (-0.39 to 0.09) | =
Nuesch et al., 2009^48^ | - SMD =0.01 (-0.18 to 0.18)^b^ | =
Nuesch et al., 2009^48^ | - SMD =-0.06 (-0.20 to 0.09)^c^ | =
Nuesch et al., 2009^48^ | Interaction of patient blinded (vs. not) and:
Nuesch et al., 2009^48^ | - Small vs. large treatment benefits: p=0.75 | =
Nuesch et al., 2009^48^ | - High vs. low between-trial heterogeneity: p=0.19 | =
Nuesch et al., 2009^48^ | - Nonpharmacologic vs. pharmacologic trial: p<0.001 (Differences more pronounced in MAs of nonpharmacologic interventions) | +
Nuesch et al., 2009^48^ | - Complementary vs. conventional medicine: p=0.07 | =
van Tulder et al., 2009,^50^ Hempel et al., 2011^55^ Dataset 1 | - Patients blinded vs. not: SMD = -0.03 (-0.18 to 0.11) | =
van Tulder et al., 2009,^50^ Hempel et al., 2011^55^ Dataset 1 | - Provider blinded vs not: SMD = -0.10 (-0.26 to 0.06) | =
Hempel et al., 2012,^74^ 2011^55^ | Dataset 2
Hempel et al., 2012,^74^ 2011^55^ | - Patient blinded vs. not: SMD =0.21 (0.04 to 0.39)^d^ | −
Hempel et al., 2012,^74^ 2011^55^ | - Provider blinded vs. not: SMD =0.19 (0.03 to 0.35)^d^ | −
Hempel et al., 2012,^74^ 2011^55^ | Dataset 3
Hempel et al., 2012,^74^ 2011^55^ | - Patient blinded vs. not: ROR=0.97 (0.78 to 1.21) | =
Hempel et al., 2012,^74^ 2011^55^ | - Provider blinded vs not: ROR=0.83 (0.67 to 1.02) | =
Hempel et al., 2012,^74^ 2011^55^ | Dataset 4
Hempel et al., 2012,^74^ 2011^55^ | - Patient blinded vs. not: ROR=0.88 (0.71 to 1.08) | =
Hempel et al., 2012,^74^ 2011^55^ | - Provider blinded vs. not: ROR=0.94 (0.77 to 1.15) | =

a +: exaggerated odds ratio from bias; =: no significant effect from bias; -: reduced odds ratio from bias

b Adjusting for allocation concealment

c Adjusting for intention-to-treat

d Point estimate is larger in blinded studies

Abbreviations: MA = meta-analyses; ROR = ratio of odds ratios; vs. = versus; SMD = standardized mean difference.

Table 10 Summary of assessor blinding risk of detection bias results by study

Study Identification | Assessor Blinding: Results of Bias | Effect^a^
Juni et al.,1999^23^ | - RRR = 0.65 (0.43 to 0.99) | +
Balk et al., 2002^30^ | - Overall: ROR = 1.02 (0.82 to 1.22) | =
Balk et al., 2002^30^ | - Cardiovascular disease: ROR = 1.11 (0.87 to 1.39) | =
Balk et al., 2002^30^ | - Infectious disease: ROR = 0.84 (0.55 to 1.27) | =
Balk et al., 2002^30^ | - Pediatrics: ROR = 1.02 (0.57 to 1.61) | =
Balk et al., 2002^30^ | - Surgery: ROR = 0.87 (0.56 to 1.36) | =
Fenwick et al., 2008^44^ | - Probing depth (adequate vs. inadequate: MD=-0.20 (-0.76 to 0.36) | =
Fenwick et al., 2008^44^ | - CAL/PAL: (adequate vs. inadequate) MD =-0.19 (-1.05 to 0.68) | =
Inaba et al., 2009^47^ | Mortality Unclear vs. no blinding: MES=0.81 (0.50 to 1.30)^a^ Yes vs. no blinding: MES =0.90 (0.51 to 0.95)^a^
Inaba et al., 2009^47^ | - CIs overlap and so difference: (p > 0.05); Incomplete ST resolution; Unclear blinding: MES=0.60 (0.42 to 0.87)^b^; Yes blinding: MES=0.82 (0.73 to 0.93)^b^ | =
Inaba et al., 2009^47^ | - CIs overlap and so difference: (p > 0.05); Impaired myocardial blush grade; Unclear blinding: MES=0.81 (0.50-1.30)^b^; Yes blinding: MES=0.90 (0.51 to 1.59)^b^ | =
Inaba et al., 2009^47^ | - CIs overlap and so difference: (p > 0.05) | =
van Tulder et al., 2009,^50^ Hempel et al., 2011^55^ Dataset 1 | - SMD: -0.10 (-0.25, 0.04) | =
Liu, LaValley, and Latham, 2011^59^ | - SMD=-0.80 (-1.35 to -0.25) | +
Liu, LaValley, and Latham, 2011^59^ | - SMD=-0.65 (-1.26 to -0.04)^c^ | +
Hempel et al., 2012,^74^ 2011^55^ | Dataset 1
Hempel et al., 2012,^74^ 2011^55^ | - SMD =-0.10 (-0.25 to 0.04) | =
Hempel et al., 2012,^74^ 2011^55^ | Dataset 2
Hempel et al., 2012,^74^ 2011^55^ | - SMD =0.06 (-0.28 to 0.41) | =
Hempel et al., 2012,^74^ 2011^55^ | Dataset 3
Hempel et al., 2012,^74^ 2011^55^ | - ROR=1.35 (1.05 to 1.73) | +
Hempel et al., 2012,^74^ 2011^55^ | Dataset 4
Hempel et al., 2012,^74^ 2011^55^ | - ROR=0.99 (0.80 to 1.22) | =
Hrobjartsson et al., 2012^60^ | Overall
Hrobjartsson et al., 2012^60^ | - ROR=0.64 (0.43 to 0.96) | +
Hrobjartsson et al., 2012^60^ | Subgroup of studies with subjective outcomes:
Hrobjartsson et al., 2012^60^ | - ROR=0.55 (0.32 to 0.95) | +
Hrobjartsson et al., 2012^60^ | Subgroup of studies with moderately subjective outcomes:
Hrobjartsson et al., 2012^60^ | - ROR=0.93 (0.56 to 1.54) | +

a +: exaggerated odds ratio from bias; =: no significant effect from bias; -: reduced odds ratio from bias

b Adjusting for study size, single or multicenter design, type of devices used, study regions, presence of conflicts of interest

c Adjusting for intention-to-treat adjustment

Abbreviations: CAL/PAL = clinical or probing attachment level; MD = mean difference; MES = mean effect size; ROR = ratio or odds ratios; RRR = ratio of relative risk; SMD =standardized mean difference.

Table 11 Summary results of studies evaluating valid statistical measures

Study Identification | Valid Statistical Measures: Results of Bias | Effect^a^
Balk et al., 2002^30^ | Overall: ROR=1.11 (0.95 to 1.31) | =
Balk et al., 2002^30^ | Cardiovascular disease: ROR=1.03 (0.81 to 1.33) | =
Balk et al., 2002^30^ | Infectious disease: ROR=1.17 (0.78 to 1.77) | =
Balk et al., 2002^30^ | Pediatrics: ROR=0.97 (0.48 to 1.73) | =
Balk et al., 2002^30^ | Surgery: ROR=1.63 (1.03 to 2.83) | -
Mhaskar et al., 2012^61^ | Prespecification of α in protocol and publication
Mhaskar et al., 2012^61^ | RHR = 1.06 (0.96 to 1.18) | =
Mhaskar et al., 2012^61^ | Prespecification of β in protocol and publication
Mhaskar et al., 2012^61^ | RHR = 1.07 (0.94 to 1.22) | =

a +: exaggerated odds ratio from bias; =: no significant effect from bias; -: reduced odds ratio from bias

Abbreviations: RHR = ratio of hazard ratios; ROR = ratio of odds ratios.

Table 12 Summary of double blinding risk of detection/performance bias results by study

Study Identification | Double Blinding Specification: Results of Bias | Effect^a^
Schulz et al., 1995^22^ | Participants, caregivers and outcome assessors all described as blinded: ROR = 0.83 (0.71 to 0.96) (p = 0.01)^b^ | +
Moher et al., 1998^26^ companion Moher et al., 1999^27^ | Composition of blinded groups not specified: ROR = 1.11 (0.76 to 1.63) | =
Linde et al., 1999^25^ | Jadad scale: patient and assessor blinded and treatment indistinguishable: ROR = 0.26 (0.14 to 0.51)^b^ | +
Kjaergard, Villumsen and Gluud, 2001^28^ | Identical placebo tablets or similar vs. not performed or tablets versus injections or similar: ROR = 0.56 (p = 0.041) | +
Kjaergard, Villumsen and Gluud, 2001^28^ | Studies with inadequate allocation concealment
Kjaergard, Villumsen and Gluud, 2001^28^ | ROR = 0.52 (0.29 to 0.92) (p = 0.024) | +
Balk et al., 2002^30^ | Patients and either caregiver or outcome assessor blinded:
Balk et al., 2002^30^ | Overall: ROR = 1.02 (0.79 to 1.24) | =
Balk et al., 2002^30^ | Cardiovascular disease: ROR = 1.10 (0.90 to 1.33) | =
Balk et al., 2002^30^ | Infectious disease: ROR = 0.71 (0.47 to 1.12) | =
Balk et al., 2002^30^ | Pediatrics: ROR = 1.05 (0.56 to 1.61) | =
Sterne et al., 2002^16^ | Composition of blinded groups not specified:
Sterne et al., 2002^16^ | Logistic regression
Sterne et al., 2002^16^ | Model-based SE: ROR = 0.68 (0.60 to 0.78) | +
Sterne et al., 2002^16^ | Robust SE: ROR = 0.68 (0.55 to 0.84) | +
Sterne et al., 2002^16^ | MA using logistic regression
Sterne et al., 2002^16^ | Fixed effects: ROR = 0.68 (0.60 to 0.78) | +
Sterne et al., 2002^16^ | Random effects: ROR = 0.67 (0.54 to 0.82) | +
Sterne et al., 2002^16^ | MA using random-effects meta-regression
Sterne et al., 2002^16^ | Fixed effects: ROR = 0.72 (0.61 to 0.85) | +
Sterne et al., 2002^16^ | Random effects: ROR = 0.71 (0.57 to 0.87) | +
Egger et al.,2003^34^ | Composition of blinded groups not specified or assessor blinded:
Egger et al.,2003^34^ | Overall: ROR = 0.88 (0.75 to 1.04) | =
Egger et al.,2003^34^ | Infectious diseases: ROR = 0.91 (0.39 to 2.17) | =
Egger et al.,2003^34^ | Neonatology: ROR = 0.88 (0.63 to 1.25) | =
Egger et al.,2003^34^ | Neurology: ROR = 0.90 (0.61 to 1.33) | =
Egger et al.,2003^34^ | Obstetrics & gynecology: ROR = 0.96 (0.66 to 1.39) | =
Egger et al.,2003^34^ | Psychiatry: ROR = 0.47 (0.26 to 0.84) | +
Egger et al.,2003^34^ | Miscellaneous: ROR = 0.97 (0.79 to 1.20) | =
Als-Nielson et al., 2003^33^ | Composition of blinded groups not specified: OR=2.9 (1.4-6.0) p =.004^b^ | +
Kyzas et al., 2005^38^ | Composition of blinded groups and level of blinding not specified; could be single or double:
Kyzas et al., 2005^38^ | Mortality
Kyzas et al., 2005^38^ | Random effects
Kyzas et al., 2005^38^ | Blinding stated: RR = 1.05 (0.86 to 1.28)
Kyzas et al., 2005^38^ | Blinding not stated: RR = 1.32 (1.06 to 1.65) | =
Kyzas et al., 2005^38^ | CIs overlap and so difference: (p > 0.05)
Kyzas et al., 2005^38^ | Fixed-effects
Kyzas et al., 2005^38^ | Blinding stated: RR = 1.05 (0.92 to 1.20)
Kyzas et al., 2005^38^ | Blinding not stated: RR = 1.29 (1.11 to 1.50) | =
Kyzas et al., 2005^38^ | CIs overlap and so difference: (p > 0.05)
Kyzas et al., 2005^38^ | Lymph node metastasis
Kyzas et al., 2005^38^ | Random effects
Kyzas et al., 2005^38^ | Blinding stated: RR = 1.15 (1.02 to 1.30)
Kyzas et al., 2005^38^ | Blinding not stated: RR = 1.18 (1.06 to 1.32) | =
Kyzas et al., 2005^38^ | CIs overlap and so difference: (p > 0.05)
Kyzas et al., 2005^38^ | Fixed-effects
Kyzas et al., 2005^38^ | Blinding stated: RR = 1.16 (1.01 to 1.34)
Kyzas et al., 2005^38^ | Blinding not stated: RR = 1.29 (1.17 to 1.42) | =
Kyzas et al., 2005^38^ | CIs overlap and so difference: (p > 0.05)
Derry et al., 2006^40^ | Double blinding of patient and assessor, practitioner (acupuncturist) could not be blinded
Derry et al., 2006^40^ | Randomized and blinded
Derry et al., 2006^40^ | Nausea: RR = 0.78 (0.58 to 1.05) | =
Derry et al., 2006^40^ | Vomiting: RR = 0.84 (0.62 to 1.14) | =
Derry et al., 2006^40^ | Antiemetic consumption: RR = 0.83 (0.64 to 1.09) | =
Derry et al., 2006^40^ | Randomized, blinded, over 100 patients
Derry et al., 2006^40^ | Nausea: RR = 0.82 (0.58 to 1.17) | =
Derry et al., 2006^40^ | Vomiting: RR = 0.79 (0.55 to 1.14) | =
Derry et al., 2006^40^ | Antiemetic consumption: RR = 0.83 (0.62 to 1.11) | =
Derry et al., 2006^40^ | Randomized, blinded, over 100 patients; control event rate ≥20%
Derry et al., 2006^40^ | Nausea: RR = 0.82 (0.58 to 1.17) | =
Derry et al., 2006^40^ | Vomiting: RR = 0.76 (0.54 to 1.05) | =
Derry et al., 2006^40^ | Antiemetic consumption: RR = 0.89 (0.69 to 1.16) | =
Pildal et al., 2007^42^ | Groups counted towards double blinding not specified; patients and caregivers reported as blinded; or placebo controlled without indication that treatments distinguishable or that investigators might have become unblinded. If only patient and assessor groups, not counted as double blinded.
Pildal et al., 2007^42^ | Data from this study only: ROR = 0.94 (0.80 to 1.10) | =
Pildal et al., 2007^42^ | Data combined from this and 6 earlier MA studies: ROR = 0.91 (0.83 to 1.00) | =
Siersma et al., 2007^13^ | Groups described as double or outcome assessor blinded
Siersma et al., 2007^13^ | Logistic regression with random effect: ROR=1.09 (0.90 to 1.33) | =
Siersma et al., 2007^13^ | Weighted regression with random effect: ROR=1.14 (0.94 to 1.39) | =
Wood et al., 2008^45^ | Groups as defined in Schulz et al., 1995,^22^ Kjaergard, Villumsen, and Gluud, 2001,^28^ and Egger et al., 2003^34^ and described in this study as double blind and using adequate methods such as identical placebo tablets or including blinding of the outcome assessor
Wood et al., 2008^45^ | Overall: ROR=0.93 (0.83 to 1.04) | =
Wood et al., 2008^45^ | Other than all-cause mortality: ROR=0.83 (0.70 to 0.98) | +
Wood et al., 2008^45^ | All-cause mortality: ROR=1.04 (0.95 to 1.14) | =
Wood et al., 2008^45^ | Interaction of blinding and outcome mortality (vs. not): (p =0.011) | +
Wood et al., 2008^45^ | Subjective outcomes: ROR=0.75 (0.61 to 0.93) | +
Wood et al., 2008^45^ | Objective outcomes: ROR=1.01 (0.92 to 1.10) | =
Wood et al., 2008^45^ | Interaction of blinding and outcome subjective (vs. not): (p=0.01) | +
Wood et al., 2008^45^ | Drug interventions: ROR=0.92 (0.81 to 1.05) | =
Wood et al., 2008^45^ | Non-drug interventions: ROR=1.00 (0.71 to 1.39) | =
Wood et al., 2008^45^ | Interaction of blinding and type of intervention: (p = 0.66) | =
Wood et al., 2008^45^ | Trials with adequate allocation concealment: ROR=1.02 (0.92 to 1.14) | =
Wood et al., 2008^45^ | Subjective outcomes: ROR=0.77 (0.65 to 0.91)^d^ | +
Wood et al., 2008^45^ | All outcomes other than mortality: ROR=0.85 (0.76 to 0.95)^d^ | +
Hartling et al., 2009^46^ supplemental analysis Memo 10 | Blinding level (single or double) not specified
Hartling et al., 2009^46^ supplemental analysis Memo 10 | In comparison to adequate blinding:
Hartling et al., 2009^46^ supplemental analysis Memo 10 | Unclear (p < 0.828)^e^ | =
Hartling et al., 2009^46^ supplemental analysis Memo 10 | Inadequate (p < 0.952)^e^ | =
Hamm et al, 2010,^52^ | Described as double blind, groups not specified
Hamm et al, 2010,^52^ | High RoB studies: SES =0.43 (0.22 to 0.65) | =
Hamm et al, 2010,^52^ | Unclear RoB studies: SES =0.39 (0.19 to 0.59) | =
Hamm et al, 2010,^52^ | Low RoB: SES =0.37 (0.25 to 0.48) | =
Hempel et al., 2011^55^ | Jadad definition: blinding score=2
Hempel et al., 2011^55^ | Dataset 3
Hempel et al., 2011^55^ | Random effects MA: ROR=1.08 (0.72 to 1.64) | =
Hempel et al., 2011^55^ | Fixed effects MA: ROR=1.05 (0.85 to 1.31) | =
Hempel et al., 2011^55^ | Schulz definition: blinded described as reported or not
Hempel et al., 2011^55^ | Dataset 3
Hempel et al., 2011^55^ | Random effects MA: ROR=1.13 (0.74 to 1.71) | =
Hempel et al., 2011^55^ | Fixed effects MA: ROR=0.92 (0.75 to 1.12) | =
Savovic et al., 2012^68^; Savovic et al., 2012^62^ Savovic et al., 2010^12^ | Described as double (groups not specified) vs. unclear or lack of double blinding
Savovic et al., 2012^68^; Savovic et al., 2012^62^ Savovic et al., 2010^12^ | All outcomes ROR = 0.86 (0.73 to 0.98)^f^ | =
Savovic et al., 2012^68^; Savovic et al., 2012^62^ Savovic et al., 2010^12^ | Mortality ROR = 1.07 (0.78 to 1.48)^f^ | =
Savovic et al., 2012^68^; Savovic et al., 2012^62^ Savovic et al., 2010^12^ | Other objective outcomes ROR = 0.91 (0.64 to 1.33)^f^ | =
Savovic et al., 2012^68^; Savovic et al., 2012^62^ Savovic et al., 2010^12^ | Subjective or mixed outcome ROR =0.77 (0.61 to 0.93)^f^ | +
Hartling et al., 2012^24^ | Double blinding based on Cochrane RoB tool
Hartling et al., 2012^24^ | High RoB studies: SMES=0.79 (0.40 to 1.18) | =
Hartling et al., 2012^24^ | Unclear RoB studies: SMES =0.77 (0.62 to 0.93) | +
Hartling et al., 2012^24^ | Low RoB studies: SMES=0.56 (0.44 to 0.68) | +
Hartling et al., 2012^24^ | Diff between RoB study groups: (p = 0.31) | =

a +: exaggerated odds ratio from bias; =: no significant effect from bias; -: reduced odds ratio from bias

b Adjusting for explicitly randomized, adequate concealment, complete followup.

c Adjusting for funding source and treatment effect (disease area and type of treatments)

d Adjusting for allocation concealment

e Adjusting for efficacy, crossover, factorial, binary outcome, and objective outcome

f Adjusting for sequence generation and allocation concealment

Abbreviation: Diff = difference; RoB = risk of bias; ROR = ratio of odds ratios; RR = risk ratio; SMES =standardized mean effect size.

Table 13 Summary of attrition bias results by study

Type of Analysis | Study Identification | Attrition Bias: Results of Bias | Effect^a^
Measure based on reporting: were numbers and reasons for withdrawals and dropouts described for each group? | Balk et al., 2002^30^ | Dropouts recorded: Yes vs. no for whether the number of dropouts was explicitly recorded or could be calculated: ROR = 1.26 (95 % CI, 0.87 to 2.05) | =
Measure based on reporting: were numbers and reasons for withdrawals and dropouts described for each group? | Balk et al., 2002^30^ | Reason for dropouts given: Yes vs. no for reasons reported for dropouts: ROR = 0.93 (95 % CI, 0.77 to 1.13) | =
Measure based on reporting: were numbers and reasons for withdrawals and dropouts described for each group?
Measure based on reporting: were numbers and reasons for withdrawals and dropouts described for each group? | Kjaergard et al., 2001^28^ | Adequate vs. inadequate followup: ROR = 1.50 (95% CI, 0.80 to 2.78) | =
Measure based on reporting: were numbers and reasons for withdrawals and dropouts described for each group? | Kjaergard et al., 2001^28^ | Subgroup analysis for large vs. small trials
Measure based on reporting: were numbers and reasons for withdrawals and dropouts described for each group? | Kjaergard et al., 2001^28^ | Large trials vs. small trials for inadequate followup: ROR = 0.72 (95% CI, 0.30 to1.71) | =
Measure based on reporting: were numbers and reasons for withdrawals and dropouts described for each group? | Kjaergard et al., 2001^28^ | Large trials vs. small trials for adequate followup: ROR = 0.58 (95% CI, 0.32 to 1.02) | =
Measure based on reporting: were numbers and reasons for withdrawals and dropouts described for each group?
Measure based on reporting: were numbers and reasons for withdrawals and dropouts described for each group? | Mhasker et al., 2012^61^ | RHR for description of dropouts: | =
Measure based on reporting: were numbers and reasons for withdrawals and dropouts described for each group? | Mhasker et al., 2012^61^ | Publication: RHR = 0.91 (95% CI, 0.72 to 1.15)
Measure based on reporting: were numbers and reasons for withdrawals and dropouts described for each group? | Mhasker et al., 2012^61^ | Protocol plus publication: RHR = 0.76 (95% CI, 0.37 to 1.55) | =
Measure based on conduct: percentage dropouts or acceptable dropouts based on a threshold | Balk et al., 2002^30^ | Percentage dropouts: results are ROR for 1 percentage-point increase in dropouts) : ROR = 1.02 (95% CI, 0.94 to 1.12) | =
Measure based on conduct: percentage dropouts or acceptable dropouts based on a threshold
Measure based on conduct: percentage dropouts or acceptable dropouts based on a threshold | van Tulder et al., 2009^50^ | Acceptable dropout (≥20% for short-term, ≥30% for long-term outcomes) SMD = -0.13 (95% CI, -0.29 to 0.02) | =
Measure based on conduct: percentage dropouts or acceptable dropouts based on a threshold
Measure based on conduct: percentage dropouts or acceptable dropouts based on a threshold | Hempel et al., 2011^74,b^ | Acceptable dropout (≥20% for short-term, ≥30% for long-term outcomes) for dataset 2 (EPC reports): SMD = 0.15 (95% CI, 0.01 to 0.29) | =
Measure based on conduct: percentage dropouts or acceptable dropouts based on a threshold | Hempel et al., 2011^74,b^ | Dataset 3 (“pro-bias”): ROR = 0.72 (95% CI, 0.59 to 0.88) | -
Measure based on conduct: percentage dropouts or acceptable dropouts based on a threshold | Hempel et al., 2011^74,b^ | Dataset 4 (“heterogeneity”): ROR = 1.02 (95% CI, 0.81 to 1.27) | =
Measure based on conduct: percentage dropouts or acceptable dropouts based on a threshold
Measure based on conduct: percentage dropouts or acceptable dropouts based on a threshold | Savovic et al., 2012^6^ | Trials with 20% of patients with missing outcome data vs. <20%
Measure based on conduct: percentage dropouts or acceptable dropouts based on a threshold | Savovic et al., 2012^6^ | All outcomes: ROR = 1.07 (95% CI, 0.92 to 1.25) | =
Measure based on conduct: percentage dropouts or acceptable dropouts based on a threshold | Savovic et al., 2012^6^ | Mortality outcomes ROR= 01.07 (95% CI, 0.80 to 1.42) | =
Measure based on conduct: percentage dropouts or acceptable dropouts based on a threshold | Savovic et al., 2012^6^ | Other objective outcomes ROR= 1.35 (95% CI, 0.63 to 2.94) | =
Measure based on conduct: percentage dropouts or acceptable dropouts based on a threshold | Savovic et al., 2012^6^ | Subjective or mixed ROR= 1.03 (95% CI, 0.79 to 1.36) | =
Measure based on a combination of reporting, conduct, and analysis: intention to treat conducted vs. no intention to treat conducted or not reported | Juni et al., 1999^23^ | ITT analysis not performed: RRR = 1.37 (95% CI, 0.92 to 2.03) | =
Measure based on a combination of reporting, conduct, and analysis: intention to treat conducted vs. no intention to treat conducted or not reported
Measure based on a combination of reporting, conduct, and analysis: intention to treat conducted vs. no intention to treat conducted or not reported | Balk et al., 2002^30^ | Yes vs. no for whether all analyzed patients were analyzed in the group to which they were originally allocated (“dropouts were allowed so long as the reasons for withdrawal were not related to the group to which they were assigned”): ROR = 0.91 (95% CI, 0.70 to 1.13) | =
Measure based on a combination of reporting, conduct, and analysis: intention to treat conducted vs. no intention to treat conducted or not reported
Measure based on a combination of reporting, conduct, and analysis: intention to treat conducted vs. no intention to treat conducted or not reported | Siersma et al., 2007^13^ | Estimates from multivariable multilevel analyses of ITT
Measure based on a combination of reporting, conduct, and analysis: intention to treat conducted vs. no intention to treat conducted or not reported | Siersma et al., 2007^13^ | Logistic regression with random effect ROR: 0.92 (95% CI, 0.79 to 1.06) | =
Measure based on a combination of reporting, conduct, and analysis: intention to treat conducted vs. no intention to treat conducted or not reported | Siersma et al., 2007^13^ | Weighted regression with random effect ROR: 1.01 (95% CI, 0.88 to 1.15) | =
Measure based on a combination of reporting, conduct, and analysis: intention to treat conducted vs. no intention to treat conducted or not reported
Measure based on a combination of reporting, conduct, and analysis: intention to treat conducted vs. no intention to treat conducted or not reported | van Tulder et al., 2009^50^ | ITT conducted | =
Measure based on a combination of reporting, conduct, and analysis: intention to treat conducted vs. no intention to treat conducted or not reported | van Tulder et al., 2009^50^ | SMD: -0.10 (95% CI, -0.24 to 0.04)
Measure based on a combination of reporting, conduct, and analysis: intention to treat conducted vs. no intention to treat conducted or not reported
Measure based on a combination of reporting, conduct, and analysis: intention to treat conducted vs. no intention to treat conducted or not reported | Hempel et al., 2011^74,b^ | ITT conducted
Measure based on a combination of reporting, conduct, and analysis: intention to treat conducted vs. no intention to treat conducted or not reported | Hempel et al., 2011^74,b^ | Dataset 2 (EPC reports): SMD = 0.05 (95% CI, -0.10 to 0.20) | =
Measure based on a combination of reporting, conduct, and analysis: intention to treat conducted vs. no intention to treat conducted or not reported | Hempel et al., 2011^74,b^ | Dataset 3 (“pro-bias”): ROR = 0.91 (95% CI, 0.74 to 1.12) | =
Measure based on a combination of reporting, conduct, and analysis: intention to treat conducted vs. no intention to treat conducted or not reported | Hempel et al., 2011^74,b^ | Dataset 4 (“heterogeneity”): ROR = 0.93 (95% CI, 0.76 to 1.14) | =
Measure based on a combination of reporting, conduct, and analysis: intention to treat conducted vs. no intention to treat conducted or not reported
Measure based on a combination of reporting, conduct, and analysis: intention to treat conducted vs. no intention to treat conducted or not reported | Mhasker et al., 2012^61^ | ITT analysis:
Measure based on a combination of reporting, conduct, and analysis: intention to treat conducted vs. no intention to treat conducted or not reported | Mhasker et al., 2012^61^ | Publication: RHR = 0.98 (95% CI, 0.90 to 1.07) | =
Measure based on a combination of reporting, conduct, and analysis: intention to treat conducted vs. no intention to treat conducted or not reported | Mhasker et al., 2012^61^ | Protocol plus publication:RHR = 0.96 (95% CI, 0.88 to 1.05) | =
Measure based on a combination of reporting, conduct, and analysis: comparisons of studies without or not reporting exclusions compared with studies reporting exclusions | Schulz et al., 1995^22^ | ROR=1.07 (95% CI, 0.94 to 1.21) p=0.32 | =
Measure based on a combination of reporting, conduct, and analysis: comparisons of studies without exclusions compared with studies with or not reporting exclusions | Tierney et al., 2004^39^ | For individual patient data, no clear indication that the exclusion of patients altered the results more in one direction than another (t=1.5337, p=0.13) | =
Measure based on a combination of reporting, conduct, and analysis: comparisons of studies without exclusions compared with studies with or not reporting exclusions | Tierney et al., 2004^39^ | For meta-analyses, tendency for HR of included patients to favor the treatment rather than HR of all patients (t=2.401, p=0.03); differences ranged between 1 and 5% | +
Measure based on a combination of reporting, conduct, and analysis: comparisons of studies without exclusions compared with studies with or not reporting exclusions (continued) | Nuesch et al., 2009^49^ | SMD = -0.13 (-95% CI, 0.29 to 0.04) p=0.13, high variability (τ2=0.07, p<0.001) | =
Measure based on a combination of reporting, conduct, and analysis: comparisons of studies without exclusions compared with studies with or not reporting exclusions (continued) | Nuesch et al., 2009^49^ | SMD for no exclusions vs. exclusions meta-analyses with low and high heterogeneity
Measure based on a combination of reporting, conduct, and analysis: comparisons of studies without exclusions compared with studies with or not reporting exclusions (continued) | Nuesch et al., 2009^49^ | Low: 0.03 (95% CI, -0.09 to 0.15) | =
Measure based on a combination of reporting, conduct, and analysis: comparisons of studies without exclusions compared with studies with or not reporting exclusions (continued) | Nuesch et al., 2009^49^ | High: -0.52 (95% CI, -0.76 to -0.27 | +
Measure based on a combination of reporting, conduct, and analysis: comparisons of studies without exclusions compared with studies with or not reporting exclusions (continued) | Nuesch et al., 2009^49^ | Interaction: (P < 0.001)
Measure based on a combination of reporting, conduct, and analysis: comparisons of studies without exclusions compared with studies with or not reporting exclusions (continued) | Nuesch et al., 2009^49^ | SMD for no exclusions vs. exclusions meta-analyses with small and large treatment benefit
Measure based on a combination of reporting, conduct, and analysis: comparisons of studies without exclusions compared with studies with or not reporting exclusions (continued) | Nuesch et al., 2009^49^ | Small: -0.03 (95% CI, -0.16 to 0.09) | =
Measure based on a combination of reporting, conduct, and analysis: comparisons of studies without exclusions compared with studies with or not reporting exclusions (continued) | Nuesch et al., 2009^49^ | Large: -0.74 (95% CI, -1.02 to -0.46) | +
Measure based on a combination of reporting, conduct, and analysis: comparisons of studies without exclusions compared with studies with or not reporting exclusions (continued) | Nuesch et al., 2009^49^ | Interaction: (P < 0.001)
Measure based on a combination of reporting, conduct, and analysis: comparisons of studies without exclusions compared with studies with or not reporting exclusions (continued) | Nuesch et al., 2009^49^ | SMD for no exclusions vs. exclusions meta-analyses with and without a drug intervention
Measure based on a combination of reporting, conduct, and analysis: comparisons of studies without exclusions compared with studies with or not reporting exclusions (continued) | Nuesch et al., 2009^49^ | Yes: -0.16 (95% CI, -0.41 to 0.09) | =
Measure based on a combination of reporting, conduct, and analysis: comparisons of studies without exclusions compared with studies with or not reporting exclusions (continued) | Nuesch et al., 2009^49^ | No: -0.05 (95% CI, -0.17 to 0.07) | =
Measure based on a combination of reporting, conduct, and analysis: comparisons of studies without exclusions compared with studies with or not reporting exclusions (continued) | Nuesch et al., 2009^49^ | SMD for no exclusions vs. exclusions meta-analyses with and without complementary medicine
Measure based on a combination of reporting, conduct, and analysis: comparisons of studies without exclusions compared with studies with or not reporting exclusions (continued) | Nuesch et al., 2009^49^ | Yes: -0.59 (95% CI, -0.87 to -0.31) | +
Measure based on a combination of reporting, conduct, and analysis: comparisons of studies without exclusions compared with studies with or not reporting exclusions (continued) | Nuesch et al., 2009^49^ | No: -0.01 (95% CI, -0.14 to 0.12) | =
Measure based on a combination of reporting, conduct, and analysis: comparisons of studies without exclusions compared with studies with or not reporting exclusions (continued) | Nuesch et al., 2009^49^ | P for interaction <0.001
Measure based on a combination of reporting, conduct, and analysis: high, unclear, or low risk of incomplete reporting based on Cochrane risk-of-bias tool | Harting et al., 2012^67^ | SES
Measure based on a combination of reporting, conduct, and analysis: high, unclear, or low risk of incomplete reporting based on Cochrane risk-of-bias tool | Harting et al., 2012^67^ | High: 0.95 (95% CI, 0.64 to 1.27) | =
Measure based on a combination of reporting, conduct, and analysis: high, unclear, or low risk of incomplete reporting based on Cochrane risk-of-bias tool | Harting et al., 2012^67^ | Unclear: 0.72 (95% CI, 0.48 to 0.95)
Measure based on a combination of reporting, conduct, and analysis: high, unclear, or low risk of incomplete reporting based on Cochrane risk-of-bias tool | Harting et al., 2012^67^ | Low: 0.62 (95% CI, 0.51 to 0.73)
Measure based on a combination of reporting, conduct, and analysis: high, unclear, or low risk of incomplete reporting based on Cochrane risk-of-bias tool | Harting et al., 2012^67^ | Overall meta-regression (p = 0.16)
Measure based on a combination of reporting, conduct, and analysis: high, unclear, or low risk of incomplete reporting based on Cochrane risk-of-bias tool | Harting et al., 2012^67^ | Stratified analysis: No variables associated with a risk of bias for incomplete data reporting.
Measure based on a combination of reporting, conduct, and analysis: high, unclear, or low risk of incomplete reporting based on Cochrane risk-of-bias tool
Measure based on a combination of reporting, conduct, and analysis: high, unclear, or low risk of incomplete reporting based on Cochrane risk-of-bias tool | Hamm et al, 2010,^52^ | High RoB: SES = 0.23 (95% CI, 0.07 to 0.39) | =
Measure based on a combination of reporting, conduct, and analysis: high, unclear, or low risk of incomplete reporting based on Cochrane risk-of-bias tool | Hamm et al, 2010,^52^ | Unclear RoB: SES = 0.45 (95% CI, 0.30 to 0.60)
Measure based on a combination of reporting, conduct, and analysis: high, unclear, or low risk of incomplete reporting based on Cochrane risk-of-bias tool | Hamm et al, 2010,^52^ | Low RoB: SES = 0.34 (95% CI, 0.21 to 0.46)
Measure based on a combination of reporting, conduct, and analysis: high, unclear, or low risk of incomplete reporting based on Cochrane risk-of-bias tool | Hamm et al, 2010,^52^ | SMD: (P > 0.05)
Measure based on reporting (undefined): complete followup or disclosure of withdrawals | Linde et al., 1999^25^ | Complete followup ROR (univariate) = 1.31(95% CI, 0.88 to 2.00) | =
Measure based on reporting (undefined): complete followup or disclosure of withdrawals | Linde et al., 1999^25^ | Complete followup ROR (multivariate) = 1.23 (95% CI, 0.85 to 1.77) | =
Measure based on reporting (undefined): complete followup or disclosure of withdrawals
Measure based on reporting (undefined): complete followup or disclosure of withdrawals | Inaba et al., 2009^47^ | Results for disclosure of withdrawals and dropouts:
Measure based on reporting (undefined): complete followup or disclosure of withdrawals | Inaba et al., 2009^47^ | (1) Mortality Unclear disclosure: ES = 0.74 (95% CI, 0.44 to 1.25) Yes: ES = 0.90 (95% CI, 0.55 to 1.47) | =
Measure based on reporting (undefined): complete followup or disclosure of withdrawals | Inaba et al., 2009^47^ | (2) Incomplete ST resolution Unclear disclosure: ES = 0.79 (95% CI, 0.65 to 0.95) Yes: ES = 0.75 (95% CI, 0.63 to 0.89) | =
Measure based on reporting (undefined): complete followup or disclosure of withdrawals | Inaba et al., 2009^47^ | (3) Impaired Myocardial Blush Grade Unclear disclosure: ES = 0.74 (95% CI, 0.44 to 1.25) Yes : ES = 0.90 (95% CI, 0.55 to 1.47) | =

a +: exaggerated odds ratio from bias; =: no significant effect from bias; -: reduced odds ratio from bias

b This row does not repeat results from dataset 1 because they appear in the row for van Tulder.

Abbreviations: CI = confidence interval; EPC = Evidence-based Practice Center; ES = effect size; ITT = intention-to-treat; SES = standardized effect size; SMD = standardized mean difference; HR = hazard ratio; RHR = ratio of hazard ratios; RoB = risk of bias; ROR = ratio of odds ratios; RRR = ratio of risk ratios.

Table 14 Summary of selective outcome reporting bias results by study

Measure of Selective Reporting | Study Identification | Selective Outcome Reporting: Results of Bias | Effect^a^
Studies with outcome published and appropriately indexed vs. published and not indexed or not published or indexed | Chan et al., 2004^37^ | Full vs. incomplete reporting
Studies with outcome published and appropriately indexed vs. published and not indexed or not published or indexed | Chan et al., 2004^37^ | Efficacy outcomes (N=50), pooled OR = 2.4 (95% CI, 1.4 to 4.0) | +
Studies with outcome published and appropriately indexed vs. published and not indexed or not published or indexed | Chan et al., 2004^37^ | Harms outcomes (N=18), pooled OR = 4.7 (95% CI, 1.8 to 12.0) | +
Studies with outcome published and appropriately indexed vs. published and not indexed or not published or indexed | Chan et al., 2004^37^ | Fully or partially vs. qualitatively or not reported
Studies with outcome published and appropriately indexed vs. published and not indexed or not published or indexed | Chan et al., 2004^37^ | Efficacy outcomes (N=35), pooled OR = 3.1 (95% CI, 1.7 to 5.9) | +
Studies with outcome published and appropriately indexed vs. published and not indexed or not published or indexed | Chan et al., 2004^37^ | Harms outcomes (N=15), pooled OR = 7.6 (95% CI, 2.3 to 25.0) | +
Comparisons of publications and protocols | Chan et al., 2004^36^ | Full vs. incomplete reporting
Comparisons of publications and protocols | Chan et al., 2004^36^ | Efficacy outcomes (N=30), pooled OR = 2.7 (95% CI, 1.5 to 5.0) | +
Comparisons of publications and protocols | Chan et al., 2004^36^ | Harms outcomes (N=4), pooled OR = 7.7 (95% CI, 0.5 to 111) | =
Comparisons of publications and protocols | Chan et al., 2004^36^ | Fully or partially vs. qualitatively or not reported
Comparisons of publications and protocols | Chan et al., 2004^36^ | Efficacy outcomes (N=20), pooled OR = 5.1 (95% CI, 2.5 to 10.0) | +
Comparisons of publications and protocols | Chan et al., 2004^36^ | Harms outcomes (N=4), pooled OR = 12.3 (95% CI, 1.5 to 99) | +
Comparisons of publications and protocols
Comparisons of publications and protocols | Kyzas et al., 2005^38^ | Fixed effects estimate for association between TP53 and HNSCC for published and indexed studies (N=18): RR = 1.23 (95% CI, 1.06 to 1.43) | +
Comparisons of publications and protocols | Kyzas et al., 2005^38^ | Fixed effects RR estimate for association between TP53 and HNSCC for published, not indexed (N=13): RR = 1.1 (95% CI, 0.99 to 1.42) | =
Comparisons of publications and protocols | Kyzas et al., 2005^38^ | Fixed effects RR estimate for association between TP53 and HNSCC for studies with information retrieved from investigators (N=11): RR = 0.98 (95% CI, 0.81, 1.19) | =
Outcome Reporting Bias in Trials (ORBIT) | Dwan et al., 2010^51^ | Intravenous magnesium: Children Hospital admission: SR results: RR = 0.69 (95% CI, 0.53 to 0.90) from 3 studies; I2 = 17.7%; Favors intervention
Outcome Reporting Bias in Trials (ORBIT) | Dwan et al., 2010^51^ | Studies suspected of ORB: 3; No. participants missing from M-A (%): 117 (50%); Sensitivity analysis: ORB alone: RR = 0.76 (95% CI, 0.58 to 0.99) | +
Outcome Reporting Bias in Trials (ORBIT) | Dwan et al., 2010^51^ | Nebulised Magnesium: Adults Hospital admission: SR results: RR = 0.68 (95% CI, 0.46 to 1.02) from 6 studies, I22 = 0; Favors intervention
Outcome Reporting Bias in Trials (ORBIT) | Dwan et al., 2010^51^ | Studies suspected of ORB: 1; No. participants missing from M-A: 74 (17%); Sensitivity analysis results w/ORB alone: RR = 0.76 (95% CI, 0.51 to 1.13); Study publication bias: 8 | +
Outcome Reporting Bias in Trials (ORBIT)
Outcome Reporting Bias in Trials (ORBIT) | Kirham et al., 2010^53^ | SRs which included a single MA of the review primary outcome (and were therefore assessed of the impact of ORB): 81 | One-third of evaluated reviews were at risk of inflated estimates of effect because of risk of bias
Outcome Reporting Bias in Trials (ORBIT) | Kirham et al., 2010^53^ | Reviews which included at least one trial that had a high suspicion of ORB: 52/81
Outcome Reporting Bias in Trials (ORBIT) | Kirham et al., 2010^53^ | Of those 52 reviews with at least one trial with high suspicion of ORB: Reviews not assessed for ORB: 27/52 Reviews assessed for ORB using maximum bias bound sensitivity analysis because c primary outcome was measured, did not have 0 events, and did not have missing studies for reasons not related to ORB: 25/52
Outcome Reporting Bias in Trials (ORBIT) | Kirham et al., 2010^53^ | Of those 25 reviews assessed for ORB using sensitivity analysis: SRs with conclusions that were robust to ORB: 8 SRs (significant effect estimate remained significant). SRs with conclusions that were not robust to ORB: 8
Cochrane risk of bias tool | Harting et al., 2012^67^ | High: SES = 0.64 (95% CI, 0.23 to 1.05)
Cochrane risk of bias tool | Harting et al., 2012^67^ | Unclear: SES = 1.18 (95% CI, 0.61 to 1.75)
Cochrane risk of bias tool | Harting et al., 2012^67^ | Low: SES = 0.64 (95% CI, 0.54 to 0.74)
Cochrane risk of bias tool | Harting et al., 2012^67^ | Overall meta-regression (p = 0.46) | =
Cochrane risk of bias tool | Harting et al., 2012^67^ | Stratified analysis: For selective outcome reporting, surgical trials showed higher risk of bias (p= 0.02) than other types of interventions and studies with industry support had higher risk of bias (p = 0.01) than studies without industry support
Cochrane risk of bias tool
Cochrane risk of bias tool | Hamm et al, 2010,^52^ | High RoB: SES = 0.52 (95% CI, 0.21 to 0.83) | =
Cochrane risk of bias tool | Hamm et al, 2010,^52^ | Unclear RoB: SES = 0.22 (95% CI, -0.19 to 0.64)
Cochrane risk of bias tool | Hamm et al, 2010,^52^ | Low RoB: SES = 0.37 (95% CI, 0.27 to 0.47) All CIs overlap
Cochrane risk of bias tool
Cochrane risk of bias tool | Hartling et al., 2011^54^ | Mean differences in effect estimates for FEV1 across domains and overall risk of bias, high/unclear vs. low risk of bias: MD = 0.01 (95% CI, -0.02 to 0.03) | =
Cochrane risk of bias tool | Hartling et al., 2011^54^ | Mean differences in effect estimates for FEV1 across domains and overall risk of bias, high vs. low/unclear risk of bias: MD = 0.01 (95% CI, -0.04 to 0.06) | =
Cochrane risk of bias tool | Hartling et al., 2011^54^ | Mean differences in effect estimates for symptom-free days across domains and overall risk of bias, high/unclear vs. low risk of bias: MD = 7.22 (95% CI, 3.68 to 10.75) | +
Cochrane risk of bias tool | Hartling et al., 2011^54^ | Mean differences in effect estimates for symptom-free days across domains and overall risk of bias, high vs. low/unclear risk of bias: MD = 3.67 (95% CI, -8.5 to 15.84) | =
Proportion of trials in a systematic review contributing to meta-analysis estimates | Furukawa et al., 2009^65^ | When outcomes favored the intervention, for each 10-point decrease in the percentage of contributing trials, increase in OR = 1.046 (95% CI, 1.004 to 1.090) SMD: = 0.041 (95% CI, 0.002 to 0.079 | +
Proportion of trials in a systematic review contributing to meta-analysis estimates | Furukawa et al., 2009^65^ | Percentage of RCTs contributing to the meta-analyses: odds ratio, mean (95% CI) <20: OR = 2.67 (1.81 to 3.94) 20 to <40: OR = 2.38 (1.72 to 3.28) 40 to <60: OR = 2.22 (1.64 to 3.01) 60 to <80: OR = 1.61 (1.36 to 1.90) ≥ 80: OR = 1.87 (1.52 to 2.31)
Proportion of trials in a systematic review contributing to meta-analysis estimates | Furukawa et al., 2009^65^ | Percentage of RCTs contributing to the meta-analyses: SMD (95% CI) <20: SMD = 0.64 (0.36 to 0.91) 20 to <40: SMD = 0.48 (0.3 to -0.62) 40 to <60: SMD = 0.56 (0.34 to 0.78) 60 to <80: SMD = 0.36 (0.22 to 0.51) ≥ 80: SMD = 0.31 (0.19 to 0.43)

* +: exaggerated effect from bias; =: no significant effect from bias; -: reduced effect from bias

Abbreviations: CI = confidence interval; FEV1 = forced expiratory volume in 1 second; HNSCC = ; MA = meta-analysis; N = number; ORB = ORBIT; RCT = randomized controlled trial; RoB: risk of bias; RR = risk ratio; SMD = standardized mean difference; SR = systematic review.

Appendix E offers an assessment of the quality for each included study.

## Results of Literature Searches

We identified 4,844 citations from searches and reviews of reference lists. Figure 1 documents the disposition of the 165 articles retrieved for full-text review for this report. We excluded 117 full-text articles for various reasons, including wrong design (narrative reviews that did not measure the effect of the bias on outcomes, studies not designed primarily to look at the effect of a bias on the size or direction of effect, such as sensitivity analyses included in systematic reviews of treatment effects; or sensitivity analyses to assess nonmethodological biases), a focus on medical tests, and biases not being considered as part of the review. These included publication bias, other biases that can occur when studies are conceived and performed (e.g., sponsorship, language, single versus multisite studies, studies stopped early for benefit, clinical specialty of the review team, and nonrandomized studies only), and other global biases that refer to atypical methodological biases and biases that can occur in analyzing the study results (e.g., different methods used to measure the summary estimate and evaluating noninferiority trials). Articles excluded during full-text review are listed in Appendix C with reasons for exclusions. The review includes 38 studies, reported in 48 publications. Three of the included studies, while meeting our inclusion criteria, did not contain any usual data for our analyses and are not discussed further.19-21

## Overview of Included Studies

Among the 35 included studies that we include as evidence, the unit of analysis for 11 of the studies was meta-analyses,6, 16, 22, 26-28, 30, 34, 42, 45, 48, 49, 56, 57, 62, 63 for 22 it was trials,23, 25, 32, 33, 35-38, 40, 44, 47, 50-52, 54, 55, 59-61, 64-67 for one it was both meta-analyses and trials,39 and for one it was systematic reviews.53 Some of the studies included data from earlier studies. Sterne et al.16 reanalyzed data included in the Schulz et al. study22 based on additional model specifications. Wood et al.45 combined data from three earlier studies included in this review—Schulz et al.,22 Kjaergard et al.,28 and Egger et al.34 Pildal et al.42 combined data from six earlier studies—Schulz et al.,22 Moher et al.,27 Kjaergard et al.,28 Egger et al.,34 Balk et al.,30 and Als-Nielson et al.43 Hempel et al. compared results among four datasets, two of which were based on studies included in other studies reported in this review—Moher et al.27 and Balk et al.30 Results of one of the datasets analyzed in Hempel et al.35, 55 were also presented in Hamm et al.52 The largest dataset was constructed by Savovic et al.,6, 12, 62 combining data from seven earlier studies, including six included in this review: Schulz et al.,22 Siersma et al.,64 Balk et al.,30 Egger et al.,34 Kjaergard et al.,28 and Pildal et al.42

While more than half of the studies were not limited to a particular condition or treatment approach or did not report on these characteristics in their included trials, 16 studies were limited to trials in particular treatment areas or approaches to treatment. Specifically, Schulz et al.22 and Sterne et al.16 were limited to obstetric and neonatal trials; Juni et al.23was limited to use of heparin in surgery trials; Linde et al.25 concerned homeopathy; Kyzas et al.,38 Tierney,39 and Mhaskar et al.61 focused on cancer outcomes; Hartling et al.66 was limited to pediatric trials; Nuesch et al.48, 49 concerned pain outcomes after treatment for osteoarthritis; Hartling et al.54 and Dwan et al.51were limited to asthma; van Tulder et al.50 focused on treatment for low back pain; Clifford et al.32 was limited to pharmaceutical interventions; Derry et al.40 treatment with acupuncture; Fenwick et al.44 periodontology; and Balk et al.30subgroup analyses limited to trials concerning cardiovascular disease, infectious disease, pediatrics, and surgery. Seven studies adjusted for the effect of other biases: Schulz et al.,22 Linde et al.,25 Wood et al.,45 Nuesch et al.48, 49, Liu et al.,59 Hrobjartsson et al.,60 and Savovic et al.6, 62 Four additional studies adjusted for other study-level characteristics: Clifford et al.32 funding source, Als-Nielsen et al.33 funding source and treatment effect, and lastly, Inaba et al.47 and Hartling et al.66 adjusted for a number of factors other than the biases being examined in this review (Tables 3 and D-2). Each specific results section below provides additional detail about the characteristics of the studies included in the evidence, including statistical approach and adjustment for other variables.

## Selection Bias: Allocation Concealment

### Description of Included Studies

#### Study Characteristics

A total of 25 studies (31 publications) met our inclusion criteria for the evaluation of selection bias, operationalized as allocation concealment, random sequence generation, or generally described as randomization. Twenty three5, 12, 13, 16, 22-28, 30, 32, 34, 42, 44-46, 48-50, 55-57, 61, 62, 68, 69 of 25 studies reported on allocation concealment. Two studies40, 47 did not distinguish between sequence generation and allocation concealment but specified the bias as randomization; however, we include the data for these studies in the allocation concealment results (Table 4).

From these 25 studies evaluating the impact of inadequate allocation concealment, three studies (five publications) reevaluated trials within previously published empirical evaluations that included data from studies also eligible for inclusion in this systematic review. From these three meta-epidemiological publications, one study55 contained bias ratings from two previously published datasets,26, 27, 50 another study45 from three datasets,22, 28, 34 and the third study12, 68 from five datasets22, 28, 30, 34, 42 eligible in our systematic review. One study16 reanalyzed the Schultz et al.22 data to assess the effect of improvements in the statistical computational methods used to estimate the impact of allocation concealment bias.

The meta-analyses and trials included in the majority of the eligible meta-epidemiological studies were derived from specialized registries for systematic reviews (predominately Cochrane) or from traditional bibliographic databases (predominately MEDLINE and EMBASE). For all meta-epidemiological studies, including those that did not base their analyses on previous datasets, there was the potential for overlap of included meta-analyses or trials across the different studies (Table 3); overlap in the years of meta/analyses/trial publication, the bibliographic sources searched, the types of disease/population areas, and the datasets that were reanalyzed account for this potential inclusion of duplicate trials across studies.

The year of publication of the included meta-analyses/trials in the meta-epidemiological studies may affect the ratings for presence or absence of allocation concealment bias, because reporting standards across time may differ. Approximately half of the meta-epidemiological studies captured and included trials published up to the year 2000,^30, 32, 57^ 2002,^12, 42, 68^ 2005,^40^ 2006,^50, 55, 61^ 2007,^5, 44, 48, 49^ and 2009.^47^ For the remaining meta-epidemiological studies, the included trials were published up to the late 1990s.

#### Definition of Allocation Concealment

Definitions of adequate concealment varied across studies (Appendix Table D-3), with the most comprehensive categorization for the presence, absence, or “unclear” category being specified by Schultz et al.;22 this definition was used by five other studies.16, 26, 27, 32, 42, 55 Seven studies based the definition from the Cochrane Handbook for the 2006 version of this tool44 and the 2008 version.5, 24, 46, 47, 54, 61 Three studies28, 30, 48 used more complex definitions (relative to Schultz). One of these studies evaluated concealment based on any of 25 different quality assessment instruments.23 A second meta-epidemiological study45 that pooled trials from three previous studies22, 28, 34 used the definitions provided within the original studies. Similarly, the third study12, 62, 68 considered any definition of allocation concealment in the original datasets; however, in this study agreement between studies for trials overlapping across different meta-epidemiological datasets were compared (individual ratings of the included trials were dichotomized into adequate and inadequate allocation concealment). One study56, 57 categorized various components of allocation concealment into six distinct categories; the first three partition out various aspects of concealing allocation; the latter three concern lack of adequate description or clearly inadequate concealment.

Four studies22, 24, 44, 54 evaluated allocation concealment in three categories (adequate, inadequate, and unclear); the remaining studies typically grouped inadequate and unclear concealment into one category. However, one of these studies22 removed trials with inadequate concealment ratings and presented results comparing adequate and unclear trials. Four studies25-27, 55 used the Jadad scale to assess allocation concealment; however, the Jadad scale does not specifically query allocation concealment. As such, one study added additional items from the Internal Validity Scale,25 which is not a validated scale, and the others added items from the Schultz definition.26, 55, 71

Two studies did not specify the criteria for establishing randomization (sequence generation and allocation concealment).40, 47

#### Population, Interventions, Comparators, and Outcomes of Included Studies

For many of the included meta-epidemiological studies evaluating allocation concealment, the types of population, interventions, comparators, or outcomes were not sufficiently specified; however, the titles of included meta-analyses or systematic reviews or trials included in the meta-epidemiological study were reviewed and, where possible, these were extracted (see Appendix D and Table 3).

Eight of the 25 studies evaluating allocation concealment included trials with specific patient or disease groups and these included trials restricted to periodontal disease,44 osteoarthritis,48, 49 acute myocardial infarction with adjunctive devices,47 back pain,50 cancer,61 and pediatric populations.5, 46 The remaining studies included a wide variety of patient and disease populations. Another study30 compared four patient/disease categories that included cardiovascular, infectious diseases, pediatrics, surgical interventions, and an overall category combining all groups. The remaining meta-epidemiological studies included meta-analyses/trials with very heterogeneous populations and diseases.

Two studies limited the included trials to acupuncture40 and pharmaceutical interventions.32 Three studies34, 45, 49 presented stratified results comparing different interventions that included drug versus nondrug interventions and estimated the impact of inadequate allocation concealment. One study49 presented stratified analyses based on complementary versus conventional medicine interventions. Overall, there was great variability in the types of interventions in the trials included across the meta-epidemiological studies.

Two meta-epidemiological studies included only trials with placebo25 or placebo, sham, and noninterventions49 comparators. Three studies had a single intervention as the comparator and this included standard percutaneous coronary intervention,47 acupuncture,40and standard weight heparin.23 A single study34 presented stratified analyses comparing active versus nonactive comparators within the included trials. The remaining studies did not specify the type of comparators of the included trials.

The majority of meta-epidemiological studies did not specify the types of outcomes, and some of these were extracted from reviewing titles of included trials in the reference list (see Table 3 and Appendix D). Fifteen studies16, 22, 23, 25-28, 30, 34, 42, 45, 57, 61, 68, 70, 72 evaluated the impact of allocation concealment using binary outcomes (Table 4). The remaining studies evaluated mean MD and SMD. Two studies compared the impact of allocation concealment on subjective versus objective outcomes,12, 45, 68 and one study compared mortality versus morbidity outcomes.12, 68

Two meta-epidemiological studies considered trial characteristics such as study sample size,48, 49 funding source,32 and method of allocation concealment,56, 57 when evaluating the impact of inadequate allocation concealment on the treatment effect.

### Findings From Studies Concerning Allocation Concealment

Table 4 shows the main findings from the studies that evaluated the impact of inadequate allocation concealment on the treatment effect. Fifteen meta-epidemiological studies estimated the ROR or ratio of hazard ratios (RHR). Across studies, a value of less than one indicates that the presence of allocation concealment bias exaggerates the treatment effect. The ROR estimates for inadequate concealment varied, and showed a general trend that the presence of this bias could exaggerate treatment effect from 52 percent28 to 8 percent;12, 68 however, not all of these estimates were statistically significant. From these 15 studies that evaluated the impact using ROR/HR, nine meta-epidemiological studies were statistically significant for some comparisons; generally all studies showed consistently that the presence of inadequate or unclear allocation concealment exaggerated the treatment effect. However, in some of the studies demonstrating statistical significance, the effects were not consistent across all conditions evaluated within the same meta-epidemiological study (see Table 4). One study29, 73 reanalyzed their results with more advanced statistical tests and showed a much smaller exaggerated effect that was only marginally significant. One study35, 55 that evaluated different datasets showed different results with different methods of assessing the risk of bias. The populations, interventions, and outcomes in the meta-epidemiological studies that were statistically significant were notably heterogeneous (see Table 3).

Nine studies measured mean difference MD or SMD to evaluate the impact of this bias. Generally, the point estimates of the MD or SMD were negative, suggesting that studies with adequate concealment had smaller treatment effects. However, among these nine studies, only three differences in estimates were statistically significant (Table 4). One study48, 49 found significant differences in the impact of inadequate concealment in trials that showed a large versus small benefit; similarly, the impact of bias in complementary versus conventional interventions was also statistically significant. However, the difference in the overall estimate (including all trials) was not significant in this meta-epidemiological study. The second study24, 69 showed that the magnitude of the treatment effect was smaller for trials at high risk of bias relative to those with low risk of bias. The third study47 reported the relative risk (RR) for three different outcomes associated with myocardial infarction and adjunctive devices. Although this study did not specify which aspects of randomization were evaluated, the findings suggest for two of these outcomes, the RR was greater in magnitude for unclear randomization compared with adequate randomization; however, the confidence intervals for all outcomes overlapped substantially.

Among the three studies evaluating the impact of allocation bias based on other considerations, the results were varied (Table 4). The findings from one study32 suggest that trials that differ by source of funding (industry only, not for profit sources, or mixed sources) or the direction of the trial findings (favoring new intervention, conventional interventions, neutral findings or unclear) did not differ with respect to whether they had unclear or clear concealment (concealment adequate or inadequate). A second study40 did not specify which aspect of selection bias associated with randomization was evaluated; the impact of the bias was assessed as a RR for selected adverse events associated with acupuncture.40 The third study47 compared each of three cardiac outcomes and showed that unclear randomization was associated with a larger pooled RR (relative to those that had adequate randomization) for all but two of the outcomes; however, the confidence intervals overlapped significantly for all outcomes.

#### Impact of Other Factors on the Effects of Allocation Concealment Bias

Only one30 of 25 meta-epidemiological studies compared the impact of inadequate allocation concealment (relative to adequate concealment) on treatment effects based on different populations (four patient disease categories—cardiovascular, infectious diseases, pediatrics, surgical interventions—and an overall category combining all groups) and showed no significant differences for any of the four disease groups or overall. However, the trials within the disease/intervention areas may still be heterogeneous with respect to patient characteristics and interventions.

The effect of inadequate concealment by the type of intervention was considered in four studies. Three of these studies presented stratified results comparing drug versus nondrug interventions with respect to inadequate allocation concealment and calculated the ROR,34, 45 or SMD.49 Only one of these studies49 showed that differences in treatment effects were larger in drug trials relative to nondrug trials (suggesting drug trials with inadequate concealment show larger treatment benefits). This same study49 presented stratified analyses based on complementary versus conventional medicine and showed no significant differences in treatment effects between these intervention groups with respect to inadequate concealment.

A single study34 presented stratified analyses comparing active versus nonactive comparators within the included trials and showed no statistical difference between those that did and did not adequately conceal allocation.

Four studies evaluated the impact of inadequate concealment on different outcomes. Two studies compared the impact on subjective (patient reported, physician assessed), objective, and mortality-related outcomes. Both studies showed that inadequate concealment exaggerated the treatment effect significantly; from 31 percent [ROR, 0.69 (0.59 to 0.82, p=0.009)]45 to 18 percent [ROR, 0.82 (0.70 to 0.94,].12, 62, 68 For objective outcomes, one study was statistically significant and the other was not.12, 62, 68 Another study44 that presented stratified analyses for three outcomes in periodontal disease found no difference in the trials with or without adequate concealment. A fourth study47 compared different outcomes associated with myocardial infarction and adjunctive devices. Although this study did not specify which aspects of randomization were evaluated, the findings suggest that the magnitude of the RR varies by the type of outcome and that for two of three outcomes the magnitude was greater when randomization was unclear; however, the confidence intervals overlapped.

Some of the studies evaluated the potential for other factors to impact the magnitude or direction of bias associated with allocation concealment. One study28 showed that among small trials only, this bias was associated with significantly exaggerated treatment effects [ROR, 0.48 (0.25 to 0.92, p=0.027)]; it was also significant in small trials when compared with large (greater than 1,000 subjects) trials [ROR, 0.49 (0.27 to 0.86, p=0.014)]. One study61 compared the impact of the protocol and the publication of a study and showed a significant difference (exaggerated effect 5 percent to 6 percent) when concealment bias was present.

## Selection Bias: Sequence Generation (Randomization)

### Description of Included Studies

#### Study Characteristics

Fourteen meta-epidemiological studies (18 publications)5, 12, 13, 22, 24-28, 30, 46, 54, 55, 61, 62, 68, 69 reported on bias associated with sequence generation during randomization. From these meta-epidemiological studies, two (four publications) reevaluated trial data from previously published empirical evaluations that were also included in this systematic review. From these two meta-epidemiological publications, one study 70contained bias information from two previously published datasets,26, 27, 50 and the second study12, 62, 68 contained bias information from five datasets22, 28, 30, 34, 42included in our systematic review.

The meta-analyses and trials included in the majority of the 14 meta-epidemiological studies evaluating the impact of poor sequence generation were derived from specialized registries for systematic reviews (predominately Cochrane) or from traditional bibliographic databases (predominately MEDLINE and EMBASE). Given the years of publication, the bibliographic databases, and the disease/intervention areas included, there was the potential for overlap of meta-analyses and trials across the meta-epidemiological studies. Eight meta-epidemiological studies captured more recently published trials, to the years 2000,^30^ 2002,^6, 62, 63^ 2006,^24, 50, 54, 55, 61^ and 2007.^5^ The remaining five meta-epidemiological studies included trials published up to the late 1990s.

#### Definition of Sequence Generation

Definitions of what was adequate and inadequate sequence generation varied across studies (Appendix Table D-4). From the 14 studies evaluating the impact of bias associated with sequence generation, two25-27 employed the Jadad scale to define adequate sequence generation (Appendix Table D-4). One study12, 62, 68 included any definition of sequence generation in the original dataset; it compared agreement between the individual trial ratings for bias from different studies and dichotomized ratings to indicate those that were deemed adequate or inadequate. Five studies used the criteria from the Cochrane Handbook version 2008.^5, 24, 46, 54, 61^ The remaining five studies13, 22, 28, 30, 50 had similar criteria for defining the presence or absence of this bias as the other meta-epidemiological studies in our systematic review.

#### Population, Interventions, Comparators, and Outcomes of Included Studies

Table 3 shows the different populations (diseases or age groups) included within the studies evaluating the impact of inadequate sequence generation. For many of the studies, the specific population, intervention, comparator, and outcome information was not fully reported; where possible, we reviewed the titles of included meta-analyses or systematic reviews and extracted information related to these characteristics (Appendix D). Overall, great variability for all these characteristics was noted across the trials included within these 14 meta-epidemiological studies.

Four of the 14 studies evaluating sequence generation included trials with specific patient or disease groups and these included trials restricted to back pain,50 cancer,61 and pediatric populations.5, 46 Another study30 compared four patient/disease categories that included cardiovascular, infectious diseases, pediatrics, surgical interventions, and an overall category combining all groups The remaining meta-epidemiological studies included a wide variety of patient and disease populations.

One study25 included only trials with placebo arms. One study had a single intervention as the comparator that included medications for persistent asthma.54 The remaining studies did not specify the type of comparators within the included trials.

The majority of studies did not specify the types of outcomes, and we derived some of these based on the titles of included meta-analyses/trials where possible. Nine studies12, 13, 22, 25-28, 30, 61, 62, 68, 70 evaluated the impact of sequence generation using the ROR. Six studies evaluated SMD,5, 50, 70 and MD.24, 46, 54, 69

### Findings From Studies Concerning Sequence Generation

Table 5 shows the findings from the meta-epidemiological studies that evaluated the potential effect of inadequate sequence generation. Nine meta-epidemiological studies estimated the ROR or RHR. A value of less than one indicates that the presence of allocation concealment bias exaggerates the treatment effect. The ROR estimates for inadequate sequence generation varied, and estimates showed the presence of this bias could exaggerate treatment effect from 51 percent28 to 5 percent;29, 70 however, not all of these estimates were statistically significant. From these nine studies that evaluated the impact using ROR/RHR, three meta-epidemiological studies were statistically significant for some comparisons. One study28, 29 used more advanced statistical computations and showed that sequence generation bias was no longer statistically significant following the revised analysis. One study12, 62, 68 found a significant difference when all outcomes were considered together but not for more specific outcomes (Table 5). Two other studies showed a significant exaggeration among studies with inadequate sequence generation; one25 showed a 36 percent amplification of the treatment effect, and the other showed the largest impact (48 percent to 51 percent) and was consistent in small and large trials.28

Six studies evaluated the impact of inadequate sequence generation using MD and SMD, and only two studies showed statistically significant differences. One of these studies5showed that the treatment effect for trials with high risk of bias was smaller than those with low risk of bias. In contrast, the second study24, 69 showed that the treatment effect in the low risk of bias trials was of a smaller magnitude than the unclear and high risk of bias groups.

#### Impact of Other Factors on the Effects of Sequence Generation

Only 1^30^ of 14 meta-epidemiological studies compared the impact of inadequate sequence generation based on different populations (four patient/disease categories—cardiovascular, infectious diseases, pediatrics, surgical interventions—and an overall category combining all groups) and showed no significant differences for any of the four groups or the overall category.

The effect of inadequate sequence generation by the type of intervention was not evaluated in any study. A single study34 presented stratified analyses comparing active versus nonactive comparators within the included trials and showed no statistical difference between those that did and did not adequately undertake sequence generation.

A single study12, 62, 68 evaluated the impact of different outcomes and showed that the presence of inadequate sequence generation did not influence the treatment effect (Table 5).

Two studies evaluated the potential for other factors and the impact on the magnitude or direction of bias associated with sequence generation. One study28 compared large versus small trials and showed that with small trials only the impact of the presence of this bias was significant [ROR, 0.49 (0.30 to 0.81, p=0.001)]; it was also significant when comparing large (greater than 1000 subjects) to small trials [ROR, 0.52 (0.28 to 0.93, p=0.029)]. One study61 compared the impact of the protocol and the publication of a study and showed no significant difference when sequence generation bias was present.

## Confounding

### Description of Included Studies

#### Study Characteristics

Two studies examined the relationship between confounding and treatment effect (Table 6).30, 50 One study calculated SMDs in a meta-analysis of back pain trials identified from a review of 15 Cochrane reviews in the 2005 issue that focused on conservative treatments for low back pain.50 The second study was a meta-epidemiological assessment of the effect of risk of bias on treatment effects, stratified by clinical condition.30

#### Definition of Confounding

One study evaluated whether baseline differences in groups that could be confounders were examined using a dichotomous response.30 The study did not specify how unclear or no information was handled. The other study considered similarity of prognostic factors at baseline and recorded responses as “yes,” “no,” or “don't know.” In order to be scored “yes,” reviewers had to agree that demographic factors, duration and severity of complaints, percentage of patients with neurologic symptoms, and value of main outcome measure(s) were similar. In the analysis, the authors combined “no” and “don't know” to generate a dichotomous judgment.50

#### Population, Interventions, Comparators, and Outcomes of Included Studies

As noted earlier, one study was limited to low back pain.50 The second study included and stratified results for three clinical conditions: infectious diseases, pediatrics, and surgery. Both included a variety of interventions within each clinical area. Neither study specified types nor limitations on comparators. As noted previously, the meta-epidemiological study assessed ratios of odds ratios,30 and the meta-analysis evaluated treatment effect differences.50

### Findings Related to Confounding

Although the newer study offered much greater specificity in identifying confounding,50 neither study found evidence that confounding influences the treatment effect of studies.30, 50 Notably, both studies included RCTs only. Even in well-conducted RCTs, a dissimilarity of prognostic variables between intervention and control arms may be expected as a matter of chance: across all possible randomizations, interventions and control arms should be similar. Such dissimilarity between arms, because it occurs at random, may not influence treatment effect consistently. As a result of their exclusive focus on RCTs, these studies may not be able to address the issue of the effect of confounding on effect size.

## Performance Bias: Fidelity to Protocol, Unintended Interventions, or Cointerventions

### Description of Included Studies

#### Study Characteristics

Two studies examined the relationship between performance bias and treatment effect (Table 7).50, 74 One study calculated treatment effect differences in a meta-analysis of back pain trials identified from a review of 15 Cochrane reviews in 2005 (216 trials) that focused on conservative treatments for low back pain.50 The second study reevaluated results from four datasets: the van Tulder analysis of back pain trials,50 an analysis of Agency for Healthcare Research and Quality (AHRQ) systematic reviews (165 trials),55 a dataset compiled by Moher et al. that demonstrated the effect of quality criteria on treatment effect27 (“pro-bias,” 100 trials), and a dataset compiled by Balk et al. that found no effect of quality criteria on most treatment effects (“heterogeneity,” 149 trials).30 No trials appeared in more than one dataset.

#### Definition of Performance Bias Measures

Both publications evaluated two measures of performance bias: fidelity to protocol and unintended interventions. They relied on the Cochrane Back Pain Review Group criteria. Specifically, for compliance, reviewers marked “yes” if there were no co-interventions or they were similar between the index and control groups, “no” for dissimilar intervention, and “don't know” for unclear information. For compliance, reviewers based their judgment on the reported intensity, duration, number, and frequency of sessions for both the index intervention and control intervention(s) and selected between “yes,” “no,” and “don't know” for responses. For single-session interventions such as surgery, reviewers marked the item as irrelevant. In all cases, the analysis compared “yes” with “not yes” responses.

#### Population, Interventions, Comparators, and Outcomes of Included Studies

The datasets cover an extremely wide range of populations, interventions, comparators, and outcomes. Of the four databases covered by this body of evidence, the van Tulder back pain group is the only one limited to a single clinical condition (nonspecific low back pain), but even this review includes numerous nonsurgical treatments.

### Findings Related to Performance Bias

Overall, the results (Table 7 and Table 8) are inconsistent in magnitude, direction, and statistical significance. The Moher et al. database stands out as the only dataset supporting a statistically significant difference in treatment effects as a result of compliance or cointerventions. Analysis of studies from the Moher et al. dataset suggest that poor compliance inflates treatment effect and dissimilar cointerventions reduce treatment effect, but neither of these conclusions is supported by the analyses of studies from the other datasets.

## Performance Bias: Patient/Caregiver or Provider Blinding

### Description of Included Studies

#### Study Characteristics

Four studies separately analyzed the effect of lack of patient, caregiver, or provider blinding.30, 35, 50 Only Balk et al.30 conducted a meta-epidemiological hierarchical analysis, nesting trials within meta-analyses. Nuesch et al. evaluated the effect of blinding, adjusting for allocation concealment in one analysis and intention-to-treat in a second and also conducted separate sensitivity analyses based on the size of the treatment benefits, trial heterogeneity, whether the treatment was pharmacologic, and whether it would be considered complementary medicine.48 The Hempel et al. study of four databases35 (also reported in van Tulder et al.50) did not adjust for the possible effect of other biases on outcomes.

#### Population, Interventions, Comparators, and Outcomes of Included Studies

Bulk et al.30 presented results overall and separately for three disease or treatment areas, while Nuesch et al.48 was limited to osteoarthritis trials. Studies of nonsurgical treatment for low back pain were presented in van Tulder et al.,50 and Hempel et al.74 also compared outcomes in three additional datasets; one concerning a diverse set of topics, one described as “pro-bias” because Moher et al.27 had found more attenuated results in biased analyses, and the last based on a subgroup of the studies included in Bulk et al.30 that exhibited heterogeneity across studies.

### Findings Related to Patient, Caregiver, and Provider Blinding

We found few significant differences in results based on either patient or provider blinding. In Bulk et al.'s eight analyses concerning patient or caregiver blinding, only one was statistically significant30 (Table 9). In addition to large confidence intervals, point estimates differed in direction across analyses; in three of the eight, the point estimate showed a larger effect in the blinded group. Nuesch et al. also found no significant differences in treatment effects, after adjusting for allocation concealment or intent to treat.48 In a sensitivity analysis, the authors found some evidence that lack of patient blinding would be more likely to increase effect estimates in nonpharmaceutical trials. The Hempel74 comparison of four datasets found a significant difference between groups in one of the four in relation to both patient and provider blinding. However, in both analyses, the treatment effect was larger in the blinded arms (opposite of the direction one would hypothesize).

## Detection Bias: Assessor Blinding

### Description of Included Studies

#### Study Characteristics and Definition of Assessor Blinding

Eight studies evaluated whether assessor blinding is related to differences in outcomes based on the results of meta-analyses.23, 30, 35, 47, 50, 59, 60 Other studies examining patient, provider, and double-blinding are described separately below. Some of the studies of double blinding include assessor blinding; however, because of combined reporting with patient and/or provider blinding, these studies cannot isolate the effect of lack of assessor blinding.

Of the studies examining assessor blinding, only Balk et al.30 conducted a meta-epidemiological hierarchical analysis, nesting trials within meta-analyses. All other studies were meta-analyses of trials. Two studies adjusted for potential confounding from other biases in their analyses. Liu et al.59 adjusted for the effect of intention to treat on outcome results; Inaba et al.47 adjusted for funding source and other issues. Hrobjartsson et al.60 focused on trials that included both blinded and nonblinded assessment within each trial.

All of the studies specifically identified the assessor as blinded, or alternatively, as not blinded or blinding was unknown. We did not find any studies evaluating the effect of lack of data analyst blinding.

#### Population, Interventions, Comparators, and Outcomes of Included Studies

Most studies were limited to one disease condition or treatment area or stratified analyses based on condition; specifically, deep vein thrombosis,23 cardiovascular disease,30 infectious disease,30 pediatrics,30 periodontology,44 acute myocardial infarction,47 low back pain,55, 75 and progressive resistance muscle strength.59 Studies commonly included a variety of interventions and comparators; those with more limited comparisons included low molecular weight heparin compared with regular heparin,23 adjunctive mechanical devices in heart procedures,47and progressive resistance muscle strength training.59

Three of the studies included categorical outcomes,23, 30, 60 two included continuous outcomes,44, 59 and three included both types of outcomes.35, 47, 50

### Findings Related to Assessor Blinding

Results were mixed in relation to whether lack of assessor blinding was related to larger outcome effects (Table 10). Although the point estimate in virtually all analyses was larger in studies without assessor blinding, the difference was statistically significant in all or some of the analyses reported in half of the eight studies.

Two studies, each limited to a particular clinical area, found significant results using regression analysis to adjust for other biases. Juni et al.23 found larger relative risk ratios in deep vein thrombosis trials measuring deep vein thrombosis and bleeding, a 35 percent exaggeration of the effect. Results continued to be significant after adjusting for concealed allocation and withdrawals (results not reported). Liu et al.59 found a significantly larger effect in unblinded progressive resistance muscle strength trials measuring muscle strength, including even more exaggerated differences after adjusting for whether study outcomes were based on an intention-to-treat analysis. Standardized mean differences were 20 percent larger without adjusting for intention to treat, increasing to 35 percent, after taking this other bias adjustment into account. Hrobjartsson et al.,60 focusing on a cross-section of studies that included both blinded and unblinded assessment, found outcomes based on unblinded assessment to be significantly exaggerated overall (ROR, 0.64) and even more so when study outcomes were subjective (ROR = 0.55).

In contrast, the Balk et al. study, based on a hierarchical model, adjusting for nesting within meta-analyses, found a small and nonsignificant difference combining all RCTs (OR, 1.02); within disease-specific subgroups, the direction of the effect of point estimates differed by subgroup.30 Comparing results across four datasets, Hempel et al. found significant differences in only one of the four, the so-called “pro-bias” dataset that had shown evidence of bias in an earlier analysis.55

## Detection Bias: Valid Statistical Methods

### Description of Included Studies and Findings

Two studies considered the effect of using valid statistical methods (Table 11). In the Balk et al. study,30 the validity of statistical methods was determined from quality rating evaluations that asked whether the methods were considered valid and appropriate by the reviewers, based on study design and outcomes of interest. Results were only significantly different in the subgroup of surgery trials, one of three clinical subgroups, ROR = 1.63 (95% CI, 1.03 to 2.83). Other point estimates were smaller; the relationship in the pediatrics studies was close to no difference but the estimate was opposite of the hypothesized direction. Mhaskar et al.61 considered whether prespecification of the α and β error would affect the treatment effect. For both, if the effect was not prespecified in the protocol and publication, the effect was larger, though relatively small, and not statistically significant.

## Detection/Performance Bias: Double Blinding

### Description of Included Studies

#### Study Characteristics

Eighteen studies evaluated whether double blinding is related to differences in outcomes based on the results of meta-analyses.5, 12, 13, 16, 22, 24, 25, 27, 28, 30, 33, 34, 38, 40, 42, 45, 46, 55, 68 Some of the studies included data from earlier studies. The Sterne et al. study16 reanalyzed data included in the Schulz et al. study22 based on additional model specifications. The Wood et al. study45 combined data from three earlier studies included in this review: Schulz et al.,22 Kjaergard et al.,28 and Egger et al.34 The Pildal et al. study combined data from six earlier studies: Schulz et al.,22 Moher et al.,27 Kjaergard et al.,28 Egger et al.,34 Balk et al.,30 and Als-Nielson et al.43 Hempel et al.55 reanalyzed data used in the Moher et al.27and Balk et al.30 studies. Savovic et al. combined data from seven earlier studies, six of which are included in this review: Schulz et al.,22 Kjaergard et al.,28 Egger et al.,34 Balk et al.,30 Als-Nielson et al.,43 and Pildal et al.42 Eight of the studies conducted meta-epidemiological studies, nesting trials within meta-analyses.16, 22, 27, 28, 30, 34, 42, 68 The modeling in six of the studies adjusted for the potential effect from other sources of bias.22, 25, 33, 45, 46, 68

#### Definition of Blinding

Blinding was generally dichotomized as double-blind versus a comparison; the description of the comparison differed across studies (i.e., not, inappropriate, inadequate, other, absent, unclear, not reported). Studies differed in the categories and specificity that was used in defining double blinding: six described themselves as double blind without specifying the two blinded groups;5, 24, 27, 33, 42, 68 one used the Jadad scale76 of 0, 1, or 2 points based on whether the study included an explicit statement that patients and evaluators were blinded and that treatments were indistinguishable;25 one only required indistinguishable treatments;28 three required that patients and either caregiver or outcome assessors were blinded;13, 30, 40 one required that either two unspecified groups were blinded or the outcome assessor;34 two using the same data required triple blinding—patients, caregivers, and outcome assessors;16, 22 one included both single and double-blinded trials;38, 46 two did not specify the level of blinding;38, 59 and two included more than one approach, incorporating more than one earlier analysis.45, 55

#### Population, Interventions, Comparators, and Outcomes of Included Studies

Seven of the eighteen studies were limited to one disease condition or treatment area, specifically, perinatal trials,16, 22 homeopathy,25 tumor suppression in head and neck cancer,38 acupuncture,40 progressive resistance muscle strength,59 and pediatrics46 (Table 3). Studies commonly included a variety of interventions and comparators; those with more limited comparisons included therapeutic or preventive interventions,34 homeopathic,25 tumor suppressor protein TP53,^38^ and acupuncture. 40Two studies evaluated differences in treatment effects based on continuous outcomes.5, 24 All other studies evaluated differences in binary outcomes.

### Findings Related to Double Blinding

We found evidence of an attenuated effect from lack of double blinding in studies with subjective outcomes. Three studies found statistically significant differences, with results in the anticipated direction34, 45, 68 (Table 12). In Egger et al. (2003) results were limited to psychiatry RCTs (ROR = 0.47); in Wood et al. (2008) and Savovic et al. (2012), results were described by the authors as subjective (more specifically, in Savovic as subjective and mixed) and point estimates were similar (ROR = 0.77).34, 45, 68 Although we know that there is some overlap in the RCTs included in these studies, we do not know the extent of the overlap, but this is likely the reason for the similarity in the findings. The Wood et al. analysis adjusted for allocation concealment, while the Savovic et al. study adjusted for allocation concealment and sequence generation.

In other studies or in relation to other types of outcomes, point estimates were generally in the expected direction, but double blinding was not associated with statistically significant differences in effect in most of the studies. We found several exceptions. In the oldest study we reviewed, Schulz et al. (1995)22 found that odds ratios were exaggerated in obstetrics studies that lacked double blinding, using a meta-epidemiological design that adjusted for meta-analysis nesting and also adjusted for other bias components (allocation concealment, sequence generation, and exclusions from followup). Using data from the Schulz et al. study, Sterne et al.16 reached a similar result, based on a variety of model specifications (logistic regression with model-based and robust standard errors, meta-analysis using logistic regression [fixed effects and random effects], and meta-analysis using random-effects meta-regression [fixed effects and random effects]), while not adjusting for other bias components. Kjaergard et al.28 found a difference in effect in pharmaceutical trials from a variety of treatment areas using a meta-epidemiological design and, further, that the effect was significantly more pronounced in smaller studies. Als-Nielson et al.33 also found a significant difference in effect in pharmaceutical trials, adjusting for funding source and treatment effect (disease area and type of treatments). Linde et al.25 found an effect in homeopathy trials, adjusting for allocation concealment and completeness of followup, but not for the clustering of RCTs in meta-analyses.

## Attrition Bias

### Description of Included Studies

#### Study Characteristics

Fifteen studies evaluated how attrition bias influences the treatment effect in meta-analyses (Table 10).6, 22, 23, 28, 30, 39, 49, 50, 52, 61, 64, 67, 74

All studies included trials published before the first CONSORT statement in 1996. Two studies provided subgroup analysis to examine the effect of small versus large trials,28 level of heterogeneity, magnitude of effect, type of intervention, type of clinical area,49 data source,74and outcome.6, 47

Some included studies focused on very specific methodological issues; the issue of attrition was secondary to the main analysis in these studies. One study evaluated a range of statistical techniques with and without accounting for random effects, other variables, and clustering at the meta-analyses level; the results below present data for the random effects multivariable multilevel model.13 A second focused on whether published methodological quality in trials reflects the quality in protocols.61

Two studies described below are related.50, 74 One study by van Tulder et al. calculated standardized mean differences in treatment effect in a meta-analysis of back pain trials identified from a review of 15 Cochrane reviews in 2005 that focused on conservative treatments for low back pain.50 As noted in the section on performance bias, the second study reevaluated results from four datasets, including the van Tulder study.

#### Definition of Attrition Bias

Of the 15 studies, 13 used dichotomous and clearly described measures of risk of bias.6, 22, 23, 28, 30, 39, 49, 50, 52, 61, 64, 67, 74 These measures varied in focus and evaluated reporting, conduct, or a combination of conduct, reporting, and analysis. Studies focusing on reporting evaluated whether individual trials provided numbers and reasons for dropouts.28, 30, 61 Studies focusing on conduct evaluated the effect of the percentage of dropouts30 or dropouts under a prespecified threshold6, 50, 74 on treatment effect. Studies focusing on a combination of reporting, conduct, and analysis evaluated the effect of intention-to-treat analysis (yes versus no or unclear) on treatment effect;23, 30, 50, 61, 64, 74 compared the effect of trials with and without exclusions (unclear combined with no exclusions22 or unclear combined with exclusions.39, 49) on treatment effect; or compared treatment effects for ratings based on the Cochrane risk of bias tool domain on incomplete reporting, with one major additional specification of considering low or unclear risk of bias in studies with less than 90 percent followup.52, 67

Two studies did not clearly describe measures of completeness of data. One study presented the judgment on completeness of followup as a dichotomous measure but did not explain how this dichotomous judgment was assigned.25 The underlying Linde Internal Validity Scale appears to be a three-point (rather than two-point) scale for studies that completely, partially, or do not report withdrawals and dropouts; no explanation was provided for how the three-point scale was translated to a two-point dichotomous judgment. One study47 distinguished between “yes” and “unclear” disclosure of withdrawals and dropouts and cited the Cochrane Handbook in doing so. The Cochrane risk-of-bias tool, however, uses the term “incomplete outcome data” and categorized the risk of bias in three ways: yes (low risk of bias), no (high risk of bias), and unclear (uncertain risk of bias).^*^ These judgments of risk of bias rely on more than just whether or not trialists disclosed information on withdrawals and dropouts: they require the reviewer to infer whether missing data were likely to relate to the true outcome and whether imputation methods, when used, were appropriate. The study did not explain how the authors arrived at judgments of “yes” or “unclear” and how these categories related to the Cochrane risk-of-bias categories.

#### Population, Interventions, Comparators, and Outcomes of Included Studies

The 15 studies that evaluate the effect of attrition bias on treatment effect vary substantially in breadth of inclusion, size, and scope.

Two studies defined populations and interventions narrowly. One study was a review of 25 trials of 5,919 patients that examined the efficacy of adjunctive devices to prevent distal embolization during acute myocardial infarctions.47 A second study was a meta-analysis of 17 trials comparing low-molecular-weight heparin with standard heparin for the prevention of postoperative thrombosis that compared 25 different scales and components.23

One study focused on the intervention, homeopathy, but did not restrict populations or specific types of homeopathy. Of the 119 studies that met inclusion criteria, 89 had sufficient data to be included in quantitative analysis.25

Three studies focused on populations but did not restrict interventions. One study found 33 eligible meta-analyses in the Cochrane Pregnancy and Childbirth Database; these meta-analyses included 250 trials and 62,091 patients.22 A second study searched the Cochrane Library, MEDLINE, EMBASE, and CINAHL for systematic reviewers and meta-analyses on osteoarthritis of the knee or hip.49 The study included 14 eligible meta-analyses with 167 trials and 41,170 patients. A third study evaluated all 429 unique consecutive Phase III trials with protocols published by eight National Cancer Institute Groups up to 2006.^61^

Some studies selected the entire eligible corpus of specific databases.64, 74 Other approaches to selecting the sample used criteria such as size, specific clinical areas, access to previous bodies of work, and so on. One study identified 14 eligible meta-analyses with 190 trials, and 136,164 patients in a search for meta-analyses of large trials on Cochrane and PubMed.28 One study selected four medical areas (cardiovascular disease, infectious disease, pediatrics, and surgery) to ensure a variety of conditions.30 The authors then selected eligible meta-analysis by searching MEDLINE and Cochrane for specific dates or issues for three of the four clinical areas; for the fourth, they relied on the yield from a previous analysis by their group. Their final database included 26 meta-analysis and 276 trials. One study focusing on individual patient data included 133 randomized controlled trials and 21,905 patients from 14 meta-analyses of various interventions for bladder, brain, lung, ovarian, and esophageal cancer. They conducted risk of bias analyses for individual trials and for meta-analyses.39 Some studies incorporated or built on past databases or collections of meta-analyses.6, 67, 74

### Findings

Within and across different measures of attrition, little evidence consistently emerges of a precise and consistent effect of attrition on treatment effect (Table 13). The three studies examining attrition bias solely through measures of reporting (did the study provide the numbers and reasons for withdrawals and dropouts for each group?) found inconsistent and imprecise differences.28, 30, 61

Likewise, studies focusing solely on the effect of the percentage of dropouts30 or dropouts under a prespecified threshold6, 50, 74 on treatment effect were inconsistent and imprecise in their findings. Studies focusing on a combination of reporting, conduct, and analysis that evaluated the effect of intention-to-treat analysis on treatment effect also found inconsistent effects with overlapping confidence intervals.23, 30, 50, 61, 64, 74 The study that collapsed “no” and “unclear” responses for exclusions found an increased association between exclusions and treatment effect, but as with other studies, the effect was imprecise.22

Evidence from two studies that collapsed “yes” and “unclear” responses for exclusion found that meta-analyses with exclusions tend to have different treatment effects,39, 49 but one study notes that the direction and extent of bias are unpredictable.49 The same study found that overall meta-analyses with exclusions of patients show a more beneficial treatment effect, but the confidence intervals around that estimate spanned the line of no difference and indicated a pronounced degree of heterogeneity. Subgroup analysis offered some insight into the source of heterogeneity: the impact of exclusions on estimates of treatment effects seemed most pronounced in “meta-analyses with large treatment benefits, meta-analyses on complementary interventions, and meta-analyses with a high degree of heterogeneity between trials. The study with access to individual patient data found no effect of exclusions on individual trials, but it did find a small effect in meta-analyses that resulted in overestimates of treatment benefit.39

The two studies using the Cochrane risk-of-bias definition of incomplete reporting had overlapping confidence intervals for all categories of bias.5, 24 The two studies using dichotomous but undefined measures of complete followup25 or disclosure of withdrawals also found no statistically significant association between their measures and treatment effect.47

No pattern emerged between the dates of publication of included studies and the results.

## Reporting Bias: Selective Outcome Reporting

### Description of Included Studies

#### Study Characteristics and Definition of Selective Outcome Reporting Bias

Attempts to identify the effect of selective outcome reporting on the treatment effect require a comparison of the pooled effects from studies with a higher risk of bias with studies with a lower risk of bias. Identifying studies at high risk of selective outcome reporting is challenging, precisely because they are not reported. Nine studies36, 38, 51, 53 examined the effect of selective outcome reporting bias on treatment effect using five different approaches to identify studies with suspected selective outcome reporting (Table 14). One study examined differences in treatment effect between studies that were appropriately indexed and studies that were not.38 Two studies compared protocols with publications to examine the differences in statistical significance between studies that fully reported outcomes in publications relative to their protocols and studies that incompletely reported outcomes in publications relative to their protocols.36, 37 Two studies51, 53 used the Outcome Reporting Bias in Trials (ORBIT) approach as a means to distinguish between high and low or no risk-of-bias studies by comparing outcomes reported in individual studies to outcomes reported across the body of evidence. Using a combination of inference and judgment, these studies assigned a risk of high, low, or no risk of bias of selective outcome reporting based on clarity around the measurement and analysis of the outcome, and whether analysis and reporting of the outcome was likely to be influenced by statistical significance of the results. Three studies evaluated the Cochrane risk of bias tool.52, 54, 67 Reviewers rate studies as low risk of bias if the protocol is available and the published results include all prespecified outcomes. Infrequently, reviewers may rate studies without protocols as low risk of bias if the published results clearly indicate that all prespecified outcomes were reported. Reviewers report a high risk of bias of selective outcome reporting for studies with a mismatch between protocols and publications, for studies providing insufficient information for a meta-analysis, or for studies that did not report outcomes that should have been reported. Reviewers may choose an unclear rating when information is insufficient to arrive at a judgment. Two studies compared treatment effects for high, low, and unclear risk of bias.67 One study testing the effect of collapsing three categories into two, specifically looking at treatment effect differences when pooling studies with high or unclear risk of bias versus low compared with pooling high versus low and unclear risk of bias.54

The fifth approach to measure the effect of selective outcome reporting evaluated the change in treatment effect with a decreasing proportion of trials in a systematic review contributing to the meta-analysis.65

#### Population, Interventions, Comparators, and Outcomes of Included Studies

The indexing study examined differences in treatment effect between studies in which the outcome in question (mortality in prognostic studies that look at the status of the tumor suppressor protein TP 53 in patients with head and neck squamous cell cancer) was published and indexed with studies that were (1) published but not indexed and (2) published studies that suggested that mortality data had been collected, provided no usable information in the publication, but then provided Kyzas and colleagues with data (“retrieved” studies). Their inclusion criteria resulted in a census of all eligible studies from MEDLINE and EMBASE, but of the eligible 64 studies that alluded to mortality information, only 42 were included in the final analysis: 22 studies could not be included because primary investigators did not respond, or because primary investigators were unable to retrieve the raw data.

One study comparing publications to protocols began with all available protocols for trials approved by the Danish Scientific-Ethical Committees for Copenhagen and Frederiksberg in 1994 and 1995 for which published articles were found.37 The authors tabulated outcomes from 122 publications from 102 trials and their protocols in a 2×2 table relating the level of outcome reporting (full versus incomplete) to the level of statistical significance (p<0.05 versus p≥0.05). Only 48 percent of trialists (49/102) responded to surveys about unreported outcomes, and only 11 trialists provided information on whether their unreported outcomes were statistically significant. The authors then pooled the odds ratio for trials with nonzero rows or columns: 50 trials provided information for efficacy outcomes, and 18 for harms. When trials were dichotomized to contrast fully or partially reported outcome with qualitatively or unreported outcomes, 35 trials provided information for efficacy outcomes, 15 for harms.

The second study used the same approach to review available protocols for trials approved for funding by the Canadian Institute for Health Research from 1990 to 1998. They tabulated 2×2 tables for 48 trials. They had a much higher response rates from primary investigators than in the Danish study: as many as 90 percent responded to their questionnaires (43/48), and 77 percent (48) provided information about unreported outcomes. As with the Canadian study, when authors pooled the odds ratio for trials with nonzero rows or columns, the number of trials dropped. Thirty trials provided information on efficacy, and 4 on harms. When trials were dichotomized to contrast fully or partially reported outcome with qualitatively or unreported outcomes, 20 trials provided information for efficacy outcomes and 4 for harms.36

The first of the two ORBIT studies is a meta-epidemiological study examining the prevalence of selective outcome reporting from 50 or 51 Cochrane collaboration review groups published in three issues of the Cochrane Library (Issue 4, 2005, Issue 1, 2007, and Issue 2, 2007).53 The authors classified 538 of 712 trials as lacking information on whether the outcome of interest was measured or analyzed. They contacted 167 trialists (31 percent) for further information and obtained responses from 65 authors (12 percent). The authors analyzed 81 in detail for an assessment of the impact of missing trial data; of these trials, 25 underwent sensitivity analysis to assess the potential change in treatment effect from selective outcome reporting bias. The second study presents the results of the approach for a single systematic review for a systematic review with 24 trials on intravenous and nebulized magnesium sulphate for acute asthma.51 Twenty-two of these trials reported on the two outcomes of interest: pulmonary function and hospital admissions, and two trials were excluded for lack of outcomes. From these numbers, the authors judged that 10 more trials could have added information on the outcomes of interest. Nine of 10 trialists responded to requests for more information. The study authors went on to report sensitivity analysis for 2 meta-analyses of hospital admissions, one with 3 included trials for children and another with 6 included trials for adults.

Of the 3 studies using the Cochrane risk-of-bias tool, one selected 154 trials at random from 616 published in December 2006 that had been previously evaluated for quality,67 the second selected 10 percent of pediatric trials (N=300) from the Cochrane Central Register of Controlled Trials published in 2007,^52^ and the third selected 107 trials included in a previous systematic review of combination long-acting beta-agonists or inhaled corticosteroids for maintenance therapy in persistent asthma.54

The single study looking at the proportion of trials in a systematic review contributing to a meta-analysis selected from the first 56 meta-analyses found 10 that met the eligibility criterion of containing 10 or more RCTs from Issue 4 of the 2005 Cochrane library.65

### Findings

The indexing study found evidence that published and indexed data (i.e., selectively reported data) were more likely to show an association than unreported or inadequately indexed data, but confidence intervals for the estimates of effect overlapped.38

Both studies evaluating the association between statistical significance and outcome reporting provide evidence that statistical significance is closely associated with selective reporting of outcomes.36, 37

Two studies using the ORBIT tool offer evidence on the question of the impact of selective outcome on treatment effect (Table 14).51, 53 The largest of these, by Kirkham and colleagues, found evidence that as many as a third of the evaluated reviews were at risk of having their findings overturned because of risk of bias.53 The other study, of a single systematic review, did not find evidence that trial results were at risk of being overturned because of selective outcome reporting, but their findings suggested that for at least one outcome, a single unpublished trial would overturn the outcome.51

By contrast, studies using the Cochrane risk-of-bias tool by and large did not demonstrate the effect of selective outcome reporting on treatment effect. This lack of effect appears to be unrelated to how uncertainty is treated: the two studies generating effect estimates for high, low, and unclear risk of bias showed overlapping treatment effects,52, 67 and the study creating a dichotomous measure of selective outcome reporting did not consistently find an effect.54

The study evaluating the changes in treatment effect with decreasing proportions of trials contributing to the meta-analysis found modest increases in treatment effect.65