# References

1 Rothman KJ, Greenland S, Lash TL. Modern Epidemiology. 3rd ed. Philadelphia, PA. Lippincott, Williams, & Wilkins. 2008.
2 West S, King V, Carey TS, et al. Systems to Rate the Strength of Scientific Evidence. Evidence Report/Technology Assessment No. 47. (Prepared by the Research Triangle Institute- University of North Carolina Evidence-based Practice Center under Contract No. 290-97-0011). AHRQ Publication No. 02-E016. Rockville, MD. Agency for Healthcare Research and Quality. Apr. 2002. http://archive.ahrq.gov/clinic/epcsums/strengthsum.pdf.
3 Deeks JJ, Dinnes J, D' Amico R, et al. Evaluating non-randomised intervention studies. Health Technol Assess. 2003;7(27):iii-iix. 1. 173. [pmid: 14499048].
4 Song F, Eastwood AJ, Gilbody S, et al. Publication and related biases. Health Technol Assess. 2000;4(10):1-115. [pmid: 10932019].
5 Higgins JPT, Green S, editors. Cochrane Handbook for Systematic Reviews of Interventions Version 5.0.1. [updated September 2008]. The Cochrane Collaboration. 2008.
6 Savovic J, Jones HE, Altman DG, et al. Influence of reported study design characteristics on intervention effect estimates from randomized, controlled trials. Ann Intern Med. Sep. 18. 2012;157(6):429-38. [pmid: 22945832].
7 Hernan MA, Hernandez-Diaz S, Robins JM. A structural approach to selection bias. Epidemiology. Sep. 2004;15(5):615-25. [pmid: 15308962].
8 Viswanathan M, Berkman ND. Development of the RTI item bank on risk of bias and precision of observational studies. J Clin Epidemiol. Feb. 2012;65(2):163-78. [pmid: 21959223].
9 Ioannidis JP. Excess significance bias in the literature on brain volume abnormalities. Arch Gen Psychiatry. 2011;68(8):773-80. [pmid: 21464342].
10 Schwarzer G, Carpenter J, Rucker G. Empirical evaluation suggests Copas selection model preferable to trim-and-fill method for selection bias in meta-analysis. J Clin Epidemiol. 2010;63(3):282-8. [pmid: 19836925].
11 Sterne JA, Egger M, Smith GD. Systematic reviews in health care: Investigating and dealing with publication and other biases in meta-analysis. [Review] [46 refs]. BMJ. 2001;323(7304):101-5. [pmid: 11451790].
12 Palma S, Delgado-Rodriguez M. Assessment of publication bias in meta-analyses of cardiovascular diseases. J Epidemiol Community Health. Oct. 2005;59(10):864-9. [pmid: 16166360].
13 Relevo R, Balshem H. Finding evidence for comparing medical interventions: AHRQ and the Effective Health Care Program. J Clin Epidemiol. Nov. 2011;64(11):1168-77. [pmid: 21684115].
14 Viswanathan M, Ansari MT, Berkman ND, et al. Assessing the Risk of Bias of Individual Studies in Systematic Reviews of Health Care Interventions. Agency for Healthcare Research and Quality Methods Guide for Comparative Effectiveness Reviews. AHRQ Publication No. 12-EHC047-EF. Rockville, MD. Agency for Healthcare Research and Quality. March. 2012. www.effectivehealthcare.ahrq.gov/.
15 Naylor CD. Meta-analysis and the meta-epidemiology of clinical research. BMJ. Sep. 13. 1997;315(7109):617-9. [pmid: 9310553].
16 Sterne JA, Juni P, Schulz KF, et al. Statistical methods for assessing the influence of study characteristics on treatment effects in ‘meta-epidemiological’ research. Stat Med. 2002;21(11):1513-24. [pmid: 12111917].
17 Odgaard-Jensen J, Vist GE, Timmer A, et al. Randomisation to protect against selection bias in healthcare trials. [Review][Update of Cochrane Database Syst Rev. 2007;(2):MR000012; PMID: 17443633]. Cochrane Database of Systematic Reviews. 2011;4. MR000012. [pmid: 21491415].
18 Shea BJ, Grimshaw JM, Wells GA, et al. Development of AMSTAR: a measurement tool to assess the methodological quality of systematic reviews. BMC Medical Research Methodology. 2007;7:10. [pmid: 17302989].
19 Bausell RB, Lee WL, Soeken KL, et al. Larger effect sizes were associated with higher quality ratings in complementary and alternative medicine randomized controlled trials. J Clin Epidemiol. 2004;57(5):438-46. [pmid: 15196613].
20 Contopoulos-Ioannidis DG, Gilbody SM, Trikalinos TA, et al. Comparison of large versus smaller randomized trials for mental health-related interventions. Am J Psychiatry. Mar. 2005;162(3):578-84. [pmid: 15741476].
21 Bafeta A, Dechartres A, Trinquart L, et al. Impact of single centre status on estimates of intervention effects in trials with continuous outcomes: meta-epidemiological study. BMJ. 2012;344:e813. [pmid: 22334559].
22 Schulz KF, Chalmers I, Hayes RJ, et al. Empirical evidence of bias. Dimensions of methodological quality associated with estimates of treatment effects in controlled trials. JAMA. 1995;273(5):408-12. [pmid: 7823387].
23 Juni P, Witschi A, Bloch R, et al. The hazards of scoring the quality of clinical trials for meta-analysis. JAMA. 1999;282(11):1054-60. [pmid: 10493204].
24 Nurmohamed MT, Rosendaal FR, Buller HR, et al. Low-molecular-weight heparin versus standard heparin in general and orthopaedic surgery: a meta-analysis. Lancet. Jul. 18. 1992;340(8812):152-6. [pmid: 1352573].
25 Linde K, Scholz M, Ramirez G, et al. Impact of study quality on outcome in placebo-controlled trials of homeopathy. J Clin Epidemiol. 1999;52(7):631-6. [pmid: 10391656].
26 Moher D, Cook DJ, Jadad AR, et al. Assessing the quality of reports of randomised trials: implications for the conduct of meta-analyses. Health Technol Assess. 1999;3(12):i-iv. 1. 98. [pmid: 10374081].
27 Moher D, Pham B, Jones A, et al. Does quality of reports of randomised trials affect estimates of intervention efficacy reported in meta-analyses?. Lancet. 1998;352(9128):609-13. [pmid: 9746022].
28 Kjaergard LL, Villumsen J, Gluud C. Reported methodologic quality and discrepancies between large and small randomized trials in meta-analyses. Ann Intern Med. 2001;135(11):982-9. [pmid: 11730399].
29 Kjaergard LL, Villumsen J, Glund C. Correction: reported methodologic quality and discrepancies between large and small randomized trials in meta-analyses. Ann Intern Med. 5. August. 2008;149(3):219. [pmid: 18942172].
30 Balk EM, Bonis PA, Moskowitz H, et al. Correlation of quality measures with estimates of treatment effect in meta-analyses of randomized controlled trials. JAMA. 2002;287(22):2973-82. [pmid: 12052127].
31 Balk EM, Bonis PAL, Lau J, et al. Allocation concealment in clinical trials (response). JAMA. 2002;288(19):2406-9. [pmid: 12435253].
32 Clifford TJ, Barrowman NJ, Moher D. Funding source, trial outcome and reporting quality: are they related? Results of a pilot study. BMC Health Services Research. 2002;2(1):18. [pmid: 12213183].
33 Als-Nielsen B, Chen W, Gluud C, et al. Association of funding and conclusions in randomized drug trials: a reflection of treatment effect or adverse events?. JAMA. 2003;290(7):921-8. [pmid: 12928469].
34 Egger M, Juni P, Bartlett C, et al. How important are comprehensive literature searches and the assessment of trial quality in systematic reviews? Empirical study. Health Technol Assess. 2003;7(1):1-76. [pmid: 12583822].
35 Hempel S, Miles J, Suttorp M, et al. Detection of Associations between Trial Quality and Effect Sizes. Methods Research Report. Prepared by the Southern California Evidence-based Practice Center under Contract No. 290-2007-10062-I. AHRQ Publication No. 12-EHC010-EF. Rockville, MD. Agency for Healthcare Research and Quality. January. 2012. [pmid: 22359777].
36 Chan AW, Krleza-Jeric K, Schmid I, et al. Outcome reporting bias in randomized trials funded by the Canadian Institutes of Health Research. CMAJ. 2004;171(7):735-40. [pmid: 15451835].
37 Chan AW, Hrobjartsson A, Haahr MT, et al. Empirical evidence for selective reporting of outcomes in randomized trials: comparison of protocols to published articles. JAMA. 2004;291(20):2457-65. [pmid: 15161896].
38 Kyzas PA, Loizou KT, Ioannidis JP. Selective reporting biases in cancer prognostic factor studies. J Natl Cancer Inst. 2005;97(14):1043-55. [pmid: 16030302].
39 Tierney JF, Stewart LA. Investigating patient exclusion bias in meta-analysis. Int J Epidemiol. 2005;34(1):79-87. [pmid: 15561753].
40 Derry CJ, Derry S, McQuay HJ, et al. Systematic review of systematic reviews of acupuncture published 1996-2005. Clin Med. 2006;6(4):381-6. [pmid: 16956145].
41 Mohammed S, Goodacre S. Intravenous and nebulised magnesium sulphate for acute asthma: systematic review and meta-analysis. Emerg Med J. Dec. 2007;24(12):823-30. [pmid: 18029512].
42 Pildal J, Hrobjartsson A, Jorgensen KJ, et al. Impact of allocation concealment on conclusions drawn from meta-analyses of randomized trials. Int J Epidemiol. 2007;36(4):847-57. [pmid: 17517809].
43 Als-Nielsen B, Chen W, Gluud LL, et al. Are trial size and reported methodological quality associated with treatment effects?. Program & Abstract Book, 12th Cochrane Colloquium. 2004;2004:102-3.
44 Fenwick J, Needleman IG, Moles DR. The effect of bias on the magnitude of clinical outcomes in periodontology: a pilot study. J Clin Periodontol. 2008;35(9):775-82. [pmid: 18840153].
45 Wood L, Egger M, Gluud LL, et al. Empirical evidence of bias in treatment effect estimates in controlled trials with different interventions and outcomes: meta-epidemiological study. BMJ. 2008;336(7644):601-5. [pmid: 18316340].
46 Treadwell J, Uhl S, Tipton K, et al. Assessing Equivalence and Noninferiority. Methods Research Report. (Prepared by the EPC Workgroup under Contract No. 290-2007-10063.). AHRQ Publication No. 12-EHC045-EF. Rockville, MD. Agency for Healthcare Research and Quality. June. 2012. www.effectivehealthcare.ahrq.gov.
47 Inaba Y, Chen JA, Mehta N, et al. Impact of single or multicentre study design on the results of trials examining the efficacy of adjunctive devices to prevent distal embolisation during acute myocardial infarction. Eurointervention. 2009;5(3):375-83. [pmid: 19736164].
48 Nuesch E, Reichenbach S, Trelle S, et al. The importance of allocation concealment and patient blinding in osteoarthritis trials: a meta-epidemiologic study. Arthritis Rheum. 2009;61(12):1633-41. [pmid: 19950329].
49 Nuesch E, Trelle S, Reichenbach S, et al. The effects of excluding patients from the analysis in randomised controlled trials: meta-epidemiological study. BMJ. 2009;339:b3244. [pmid: 19736281].
50 van Tulder MW, Suttorp M, Morton S, et al. Empirical evidence of an association between internal validity and effect size in randomized controlled trials of low-back pain. Spine (Phila Pa 1976). Jul. 15. 2009;34(16):1685-92. [pmid: 19770609].
51 Dwan K, Gamble C, Kolamunnage-Dona R, et al. Assessing the potential for outcome reporting bias in a review: a tutorial. Trials. [Electronic Resource]. 2010;11:52. [pmid: 20462436].
52 Hamm MP, Hartling L, Milne A, et al. A descriptive analysis of a representative sample of pediatric randomized controlled trials published in 2007. BMC Pediatr. 2010;10:96. [pmid: 21176224].
53 Kirkham JJ, Dwan KM, Altman DG, et al. The impact of outcome reporting bias in randomised controlled trials on a cohort of systematic reviews. BMJ. 2010;340:c365. [pmid: 20156912].
54 Hartling L, Bond K, Vandermeer B, et al. Applying the risk of bias tool in a systematic review of combination long-acting beta-agonists and inhaled corticosteroids for persistent asthma. [Review]. PLoS ONE. [Electronic Resource]. 2011;6(2):e17242. [pmid: 21390219].
55 Hempel S, Suttorp MJ, Miles JNV, et al. Empirical Evidence of Associations Between Trial Quality and Effect Sizes. Methods Research Report. (Prepared by the Southern California Evidence-based Practice Center under Contract No. 290-2007-10062-I). AHRQ Publication No. 11-EHC045-EF. Rockville, MD. Agency for Healthcare Research and Quality. June. 2011. http://effectivehealthcare.ahrq.gov. [pmid: 21834174].
56 Herbison P, Hay-Smith J, Gillespie WJ. Adjustment of meta-analyses on the basis of quality scores should be abandoned. [Review] [60 refs]. J Clin Epidemiol. 2006;59(12):1249-56. [pmid: 17098567].
57 Herbison P, Hay-Smith J, Gillespie WJ. Different methods of allocation to groups in randomized trials are associated with different levels of bias. A meta-epidemiological study. J Clin Epidemiol. 2011;64(10):1070-5. [pmid: 21474279].
58 Herbison P, Hay-Smith J, Gillespie WJ. Adjustment of meta-analyses on the basis of quality scores should be abandoned. J Clin Epidemiol. 2006;59(12):1249-56. [pmid: 17098567].
59 Liu CJ, LaValley M, Latham NK. Do unblinded assessors bias muscle strength outcomes in randomized controlled trials of progressive resistance strength training in older adults?. Am J Phys Med Rehabil. Mar. 2011;90(3):190-6. [pmid: 21173683].
60 Hróbjartsson A, Thomsen AS, Emanuelsson F, et al. Observer bias in randomised clinical trials with binary outcomes: systematic review of trials with both blinded and non-blinded outcome assessors. BMJ. 2012;344:e1119. [pmid: 22371859].
61 Mhaskar R, Djulbegovic B, Magazin A, et al. Published methodological quality of randomized controlled trials does not reflect the actual quality assessed in protocols. J Clin Epidemiol. Jun. 2012;65(6):602-9. [pmid: 22424985].
62 Savović J, Harris RJ, Wood L, et al. Development of a combined database for meta-epidemiological research. Research Synthesis Methods. 2010;1(3-4):212-25.
63 Savovic J, Jones H, Altman D, et al. Influence of reported study design characteristics on intervention effect estimates from randomised controlled trials: combined analysis of meta-epidemiological studies. Health Technol Assess. Sep. 2012;16(35):1-82. [pmid: 22989478].
64 Siersma V, Als-Nielsen B, Chen W, et al. Multivariable modelling for meta-epidemiological assessment of the association between trial quality and treatment effects estimated in randomized clinical trials. Stat Med. 2007;26(14):2745-58. [pmid: 17117373].
65 Furukawa TA, Watanabe N, Omori IM, et al. Association between unreported outcomes and effect size estimates in Cochrane meta-analyses. JAMA. 2007;297(5):468-70. [pmid: 17284696].
66 Hartling L, Ospina M, Liang Y, et al. Risk of bias versus quality assessment of randomised controlled trials: cross sectional study. BMJ. 2009;339:b4012. [pmid: 19841007].
67 Hartling L, Hamm M, Milne A, et al. Validity and inter-rater reliability testing of quality assessment instruments. (Prepared by the University of Alberta Evidence-based Practice Center under Contract No. 290-2007-10021-I.) AHRQ Publication No. 12-EHC039-EF. Rockville, MD. Agency for Healthcare Research and Quality. March. 2012. www.effectivehealthcare.ahrq.gov/reports/final.cfm. [pmid: 22536612].
68 Lim B, Manheimer E, Lao L, et al. Acupuncture for treatment of irritable bowel syndrome. Cochrane Database Syst Rev. 2006;4(4). CD005111. [pmid: 17054239].
69 Hartling L, Hamm MP, Milne A, et al. Testing the risk of bias tool showed low reliability between individual reviewers and across consensus assessments of reviewer pairs. J Clin Epidemiol. Sep. 2013;66(9):973-81. [pmid: 22981249].
70 Linde K, Ramirez G, Mulrow CD, et al. St John's wort for depression--an overview and meta-analysis of randomised clinical trials. BMJ. Aug. 3. 1996;313(7052):253-8. [pmid: 8704532].
71 Agarwal R, Aggarwal AN, Gupta D. Role of noninvasive ventilation in acute lung injury/acute respiratory distress syndrome: a proportion meta-analysis. Respir Care. 2010;55(12):1653-60. [pmid: 21122173].
72 Oakley JE, Brennan A, Tappenden P, et al. Simulation sample sizes for Monte Carlo partial EVPI calculations. J Health Econ. 2010;29(3):468-77. [pmid: 20378190].
73 Dave M, Elmunzer BJ, Dwamena BA, et al. Primary sclerosing cholangitis: meta-analysis of diagnostic performance of MR cholangiopancreatography. Radiology. 2010;256(2):387-96. [pmid: 20656832].
74 Hempel S, Miles J, Suttorp M, et al. Detection of Associations between Trial Quality and Effect Sizes. Methods Research Report. Prepared by the Southern California Evidence-based Practice Centerunder Contract No. 290-2007-10062-I. AHRQ Publication No. 12-EHC010-EF. Rockville, MD. Agency for Healthcare Research and Quality. January. 2012. [pmid: 22359777].
75 Furlan AD, Tomlinson G, Jadad AA, et al. Examining heterogeneity in meta-analysis: comparing results of randomized trials and nonrandomized studies of interventions for low back pain. Spine (Phila Pa 1976). 2008;33(3):339-48. [pmid: 18303468].
76 Jadad AR, Moore RA, Carroll D, et al. Assessing the quality of reports of randomized clinical trials: is blinding necessary?. Control Clin Trials. Feb. 1996;17(1):1-12. [pmid: 8721797].
77 Dechartres A, Charles P, Hopewell S, et al. Reviews assessing the quality or the reporting of randomized controlled trials are increasing over time but raised questions about how quality is assessed. J Clin Epidemiol. 2011;64(2):136-44. [pmid: 20705426].
78 Clark T, Berger U, Mansmann U. Sample size determinations in original research protocols for randomised clinical trials submitted to UK research ethics committees: review. BMJ. 2013;346:f1135. [pmid: 23518273].
79 Chess LE, Gagnier J. Risk of bias of randomized controlled trials published in orthopaedic journals. BMC Med Res Methodol. 2013;13:76. [pmid: 23758875].
80 Ioannidis JP, Evans SJ, Gotzsche PC, et al. Better reporting of harms in randomized trials: an extension of the CONSORT statement. Ann Intern Med. 2004;141(10):781-8. [pmid: 15545678].
81 Norris SL, Holmer HK, Ogden LA, et al. Selective outcome reporting as a source of bias in reviews of comparative effectiveness. [Internet]. Agency for Healthcare Research and Quality. Report No.: 12-EHC110-EF. Rockville, MD. Aug. 2012. [pmid: 22993870].