# Methods

## Literature Search Strategy

We conducted focused searches of MEDLINE (via PubMed), the Cochrane methods group library, and the Evidence-based Practice Center (EPC) methods library located at the Agency for Healthcare Research and Quality AHRQ's Effective Health Care Program's Scientific Resource Center. We also asked members of our Technical Expert Panel and others knowledgeable of this body of work to identify relevant studies. An experienced research librarian used a predefined list of search terms and medical subject headings (MeSH). The librarian completed the MEDLINE and Cochrane methods library search on January 8, 2012, and an update search on September 24, 2012. The EPC methods library search was completed on December 5, 2011. We limited the search to studies published in English, based on limited resources. The complete search strategies for the MEDLINE and Cochrane methods library searches, including specific limitations used for each database, are presented in Appendix A. The EPC methods library search used the term “bias” with “effect,” “estimate,” “empiric,” and/or “evidence”.

## Inclusion and Exclusion Criteria

The study's inclusion and exclusion criteria are presented in Table 2. We excluded publication bias because it is not a threat to internal validity and it has been studied extensively in earlier reviews.9-14 We focused on studies that were primarily methodological and intended to evaluate the relationship between biases in study design and/or conduct and effect estimates of outcomes by comparing treatment effects in randomized controlled trials (RCTs) that implemented an approach to minimize bias (i.e., allocation concealment, blinding) with those that did not. We excluded sensitivity analyses occurring within a single systematic review or meta-analysis that was primarily evaluating treatment effects.

Table 2 Study inclusion and exclusion criteria

Category | Inclusion | Exclusion
Population, intervention, comparators, and length of followup, setting | - All populations, length of followup, and setting | - Medical tests (screening, diagnosis, genetic tests); - In vitro studies
Time period | - Published 1980 onward | - Published before 1980
Study design | - Meta-epidemiology study of randomized controlled trials; - Simulation studies for outcome reporting bias only | - Meta-epidemiology studies of observational studies
Outcomes | - Differences in treatment effect size and directions; - Difference in significance of effect | - Estimates of heterogeneity
Publication language | - English | - Non-English languages
Admissible evidence for on patient-level, provider-level, or systems-level interventions (study design and other criteria) | - Meta-analyses of data from systematic reviews that were designed primarily to examine the effect of biases on results; - Meta-epidemiological studies; - Simulation studies for outcome reporting bias only | - Primary data; - Simulation studies of the effect of biases other than outcome reporting bias; - Narrative reviews; - Studies not designed primarily to look at the effect of a bias on the size or direction of effect, such as sensitivity analyses included in systematic reviews of treatment effects.; - Studies of the potential effect of other types of biases not related to study conduct (for example, the presence of dampness vs. nondampness in asthma studies, adjusted vs. nonadjusted meta-analyses and the impact on the summary estimate)
Biases | - Selection, detection, performance, attrition, and outcome reporting. Table 1 includes the specific approaches to adjusting for the bias that are examined in studies. | - Publication bias (including time-lag bias, multiple citation bias, language bias); - Other possible sources of biases such as single versus multicenter, country of origin

We did not impose any inclusion restrictions on the manner in which the evaluation of the impact of a bias was defined or measured by a study author. For example, we included any evaluative definition of appropriate statistical methods or intention-to-treat analysis and noted the definition used in each study. Similarly, we included any approach to measurement (continuous or categorical) or formulation of the comparison group (not adjusted, not reported, or both).

Meta-epidemiological studies are commonly conducted to answer the methodological questions of interest in this review. A meta-epidemiological study analyzes a collection of meta-analyses, in each of which the component studies have been classified according to some study-level characteristic.15, 16 To include the largest number of informative studies, we did not require that included meta-epidemiological studies conduct any, or any particular type, of statistical analysis of the included meta-analyses. These studies are sometimes called meta-meta-analyses.

When describing a meta-epidemiological study, we considered the target population of meta-analyses, how the study meta-analyses were chosen, and how the number of studies that were included was justified and described. The target population refers to the population of meta-analyses from which the study meta-analyses were taken. For example, the target population might be “all meta-analyses in Cochrane Library between data X and date Y that had at least one RCT.” The target population may be representative of a certain clinical condition only, for example, meta-analyses of back pain. We also noted the list, or to use sampling language, the sampling frame from which the meta-analyses were drawn. We noted the inclusion and exclusion criteria, if appropriate. For example, only meta-analyses that contained at least one RCT were included. Finally, the target population of meta-analyses was described, either a census, that is, all meta-analyses within the population, or a random or convenience sample of meta-analyses chosen from the population.

We considered several aspects of the meta-epidemiological studies when assessing the possible influence of bias on the size and direction of the treatment effect. These aspects are the design of the meta-epidemiological study, particularly how the component meta-analyses were gathered and the resulting generalizability of the study; the measurement approach the study used to assess the biases within the trials; and the analytic approach in the study, such as whether the study fit a regression model to evaluate the relationship between the bias and treatment effect and whether the regression model adjusted for other factors (such as clinical condition).

Many meta-epidemiological studies in our systematic review fit a regression model to examine the relationship between an approach to adjusting a bias component of interest listed in Table 1 (e.g., blinded versus unblinded) and treatment effect. The descriptions of these models varied across the studies. Therefore, we now define terms that we used to classify different models based on how the meta-epidemiological study reported how its analysis was conducted. We note that in some cases, analytic approaches are comparable. If the meta-epidemiological study—

- Does not fit a regression model, but rather pools treatment effects (e.g., odds ratios) separately for different subgroups of individual trials, we call this a stratified by bias component analysis. For example, a meta-epidemiological study may pool odds ratios for all trials that are blinded and separately pool odds ratios for all trials that are not blinded. If the analysis is stratified by clinical condition, we call this a stratified by clinical condition analysis. For example, a meta-epidemiological study may pool odds ratios for all surgical trials and separately pool odds ratios for all nonsurgical trials. Both of these are stratified rather than regression approaches. We note that this type of stratified approach is comparable to a regression approach in which one interacts the stratum variable, e.g., clinical conduction, with the other terms in a regression model. If the analysis fits a hierarchical regression model in which the first level of hierarchy is trial, and the second is meta-analysis, we call this a hierarchical model. Otherwise, if the model is not hierarchical, we call this a regression model.
- Fits a regression model that includes the bias component of interest and other bias components, thereby adjusting for the effects of other biases, we say this model adjusts for other biases, that is includes multiple sources of bias. Otherwise, we say this model does not adjust for other biases. We note that the biases we considered in this assessment are those that we have chosen to study in this systematic review (Table 1); so, for example, publication bias is not included in this set of biases.
- Fits a regression model that includes other factors not among the set of biases we are studying, we say this model adjusts for other factors; otherwise, we say this model does not adjust for other factors. We note that the choice of other factors can be quite extensive (for example, types of interventions or diseases or biases that are not being studied as part of this systematic review), because it depends on what the various meta-epidemiological studies report. These factors may or may not be plausible sources of bias or modifiers of the effects of the bias components that we are interested in.

As an example of the language described above, if the authors fit a hierarchical regression model that included a single bias component (such as concealment of allocation) as an independent variable, then we describe this model of the effect of concealment of allocation as “hierarchical regression; does not adjust for other biases; does not adjust for other factors.”

We note that meta-epidemiological studies which stratify by clinical condition, or which adjust for clinical condition as another factor, produce a summary effect for each clinical topic. Conversely, meta-epidemiological studies which do not stratify by clinical condition, or which do not adjust for clinical condition as another factor, give us an average effect across clinical topics.

A discussion of modeling approaches is available in Sterne et al.16 This paper describes the theoretical basis for modeling decisions, such as the manner in which the errors are estimated; such distinctions are beyond the scope of our review. We also note that Odgaard-Jensen et al.17 further categorized meta-epidemiological studies as to whether they adjusted for clinical differences in the participants and in the interventions.

We did not conduct our own meta-analysis of the meta-epidemiological studies. This decision was based on the dissimilarity in modeling approaches across the meta-epidemiological studies and practical constraints.

In relation to our presentation of results from the included studies, we use the term “treatment effect” to mean any statistic that measures the treatment effect, e.g., a mean difference (MD), a standardized mean difference (SMD), or a dichotomous outcome measure such as a ratio of odds ratios (ROR).

In relation to our presentation of continuous outcomes, we use the Cochrane Collaboration Glossary (http://www.cochrane.org/glossary) to define a MD to be equal to the estimated mean outcome for the treatment group minus the estimated mean outcome for the control group. We define a SMD to be equal to the mean difference divided by an estimate of the standard deviation.

In studies, a MD may be called a weighted mean difference, as MDs are combined meta-analytically using weights proportional to the precision of the estimate. Sometimes a SMD is called an effect size, a measure without units. Occasionally a MD is also called an effect size. We examined each study to determine whether a MD or a SMD had been estimated using the Cochrane definitions. For greater clarity, we generally do not use the term “effect size” in this document.

## Study Selection

Two trained members of the research team independently reviewed all titles and abstracts identified through searches for eligibility against predefined inclusion and exclusion criteria. Studies marked for possible inclusion by either reviewer underwent a full-text review. Each full-text article was again independently reviewed by two trained members of the team to determine if it met inclusion criteria. If it did not meet inclusion criteria, each reviewer recorded the reason for exclusion and they later resolved the disagreement by consensus discussion. The reviewers consulted a third party if they were unable to reach a consensus. The full-text review form reviewers used is reproduced in Appendix B. Forms were created and accessed using Web-based systematic review software (DistillerSR, Evidence Partners, Ottawa, Canada). If both reviewers agreed that a study did not meet the eligibility criteria, it was excluded. If the reviewers disagreed, they resolved conflicts by discussion and consensus or by consulting a third member of the review team. The project coordinator tracked results of the abstract and full-text reviews in an EndNote database. Appendix C contains a complete list of studies excluded during the full-text review, denoted by their primary reason for exclusion.

## Data Extraction

We developed an evidence table template for data synthesis. For studies that met inclusion criteria, we abstracted relevant information into these evidence tables using Microsoft Excel. We abstracted characteristics of the study including sources of bias examined, outcomes, and inclusion/exclusion criteria and results, including how a bias was measured, statistical approach to measuring differences in outcomes (e.g., odds ratios, RORs), numeric findings, and whether the study adjusted for other biases or other factors. One trained reviewer initially abstracted the relevant data from each included study, and a second member of the team reviewed each data abstraction against the original article for completeness and accuracy.

## Quality Assessment

We developed a priori nine criteria by consensus to assess studies for potential design flaws because no standardized checklist exists. In part, our choice of questions for systematic reviews was based on AMSTAR.18 For each included study, two independent reviewers assessed the potential for bias: selection, performance, attrition, detection, and reporting. Disagreements between the two reviewers were resolved by discussion and consensus or by consulting a third member of the team. Our nine criteria included the following:

1. Were studies selected by a census? If no, how was the sample selected? Was the sample a census or not?
2. Did the study account for interaction among sources of bias?
3. Did the study use dichotomous measures for high versus low quality?
4. If the study used dichotomous measures for high versus low quality, how was the threshold determined?
5. What was the interrater reliability of risk of bias measure?
6. Was the risk of bias measure valid?
7. How was sample size calculated?
8. Do the findings of this meta-epidemiological study apply to multiple clinical areas?
9. Did the study account for duplication of trials (from different meta-analyses)?