# Peer Reviewers

Prior to publication of the final evidence report, EPCs sought input from independent Peer Reviewers without financial conflicts of interest. However, the conclusions and synthesis of the scientific literature presented in this report does not necessarily represent the views of individual reviewers.

Peer Reviewers must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential nonfinancial conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential nonfinancial conflicts of interest identified.

The list of Peer Reviewers follows:

- Ethan Balk, M.D., M.P.H.
  Tufts Center for Clinical Evidence Synthesis
  Institute for Clinical Research and Health
  Policy Studies
  Tufts Medical Center
  Boston, MA
- Gerald Gartlehner, M.D., M.P.H.
  Danube University
  Krems, Austria
- Lisa Hartling, Ph.D.
  University of Alberta
  Edmonton, Alberta, Canada
- Julian Higgins, Ph.D.
  University of Bristol
  Bristol, UK
- Joseph Lau, M.D.
  Brown University
  Providence, RI
- David Moher, Ph.D.
  Ottawa Hospital Research Institute
  Ottawa, Ontario, Canada
- Susan L. Norris M.D., M.Sc., M.P.H.
  Oregon Health and Science University
  Portland, OR
- Paul Shekelle, M.D., Ph.D.
  RAND
  Santa Monica, CA
- Jonathan Sterne, Ph.D.
  University of Bristol
  Bristol, UK
- Jonathan Treadwell, Ph.D.
  ECRI
  Plymouth Meeting, PA