# Technical Expert Panel

In designing the study questions and methodology at the outset of this report, the EPC consulted several technical and content experts. Broad expertise and perspectives were sought. Divergent and conflicted opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design, methodologic approaches, and/or conclusions do not necessarily represent the views of individual technical and content experts.

Technical Experts must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential conflicts of interest identified.

The list of Technical Experts who participated in developing this report follows:

- Ethan Balk, M.D., M.P.H.
  Institute for Clinical Research and Health
  Policy Studies Tufts Medical Center
  Boston, MA
- Julian Higgins, Ph.D.
  University of Bristol
  Bristol, UK
- David Moher, Ph.D.
  Ottawa Hospital Research Institute
  Ottawa, Ontario, Canada
- Jonathan Sterne, Ph.D.
  University of Bristol
  Bristol, UK
- Jonathan Treadwell, Ph.D.
  ECRI
  Plymouth Meeting, PA