# Acknowledgments

The authors thank our Research Assistant Priyanka Sista for the support she provided to the senior researchers through the peer review portion of this project. We would also like to thank Maureen Rice, Mary Gauld, and Julianna Beckett at the McMaster EPC, who assisted with literature identification, retrieval, and review. Lastly, we acknowledge the expert document preparation provided by Loraine Monroe at RTI International.