# Discussion

This systematic review has attempted to evaluate the impact of systematic error due to study conduct and reporting on the treatment effects estimated in randomized controlled trials (RCTs). We qualitatively synthesized the methods and results of 38 studies that separately considered approaches to evaluating the impact of protection against all or some of six bias domains as follows:

1. Selection bias at baseline through randomization (sequence generation and allocation concealment)
2. Confounding through design or analysis
3. Detection bias through assessor blinding and adequate statistical methods
4. Performance bias through fidelity to the protocol (protection against unintended interventions) and blinding (patient/provider and double)
5. Attrition bias through intention-to-treat or other approaches to accounting for loss of participants
6. Reporting bias through detection of selective outcome reporting

In summary, although a trend toward exaggeration of treatment effects was seen across the bodies of evidence for most biases, the magnitude and precision of the effect varied widely across studies. We generally found evidence that was precise and consistent in direction of effect for assessor and double blinding among studies with subjective outcomes, and for selective outcome reporting. Evidence was generally consistent in direction of effect but with variable precision across studies for allocation concealment, sequence generation, and assessor blinding of objective or mixed outcomes. In contrast, evidence was generally inconsistent and imprecise in relation to confounding, adequate statistical methods, fidelity to the protocol, patient/provider blinding, and attrition bias.

## Key Considerations Across Studies

Our synthesis was complicated by a number of factors. First, studies employed different comparisons in evaluating the risk of a bias. This conclusion was also noted by Dechartres et al.,77 who recently conducted a systematic review intended as an overview of studies (n=177) assessing the methodological quality or reporting of randomized trials; excluding studies that assessed the impact of methodological quality on treatment effect. They observed that the criteria used to assess bias was markedly heterogeneous and often insufficiently defined.77 Our systematic review, focusing only on studies that evaluated the impact of a bias on treatment effect, observed a similar problem: different studies employed different definitions of the approach to protecting against a bias. For example, only some considered inadequate study conduct separately from lack of sufficient reporting. Among the three studies that combined previous meta-epidemiological datasets,6, 42, 45, 62, 63 only one, Savovic et al.,6, 62, 63 attempted to establish some general agreement across datasets in approach to assessment of bias. The varying methods used to assess bias may be an important source of heterogeneity that resulted in the inconsistency of finding statistically significant results.

Further, assessing bias must also rely on sufficient reporting in addition to the planned and actual conduct of the study. A recent study by Mhaskar et al.61 compared risk-of-bias assessments in trial protocols relative to those reported in the subsequent publication from 429 cancer-related RCTs and found that the methods reported in the published manuscripts did not reflect the methods described in the protocols of the trials. These study authors found that associations between methodological quality and treatment effect did not persist when they evaluated study conduct based on protocols rather than published trials.61 Because meta-epidemiological studies, such as those included in our review, generally rely on assessments of the risk of bias from meta-analyses in included studies, rather than more direct observations of the trials themselves, they risk conflating the relationship between reporting of bias and treatment effect with that of actual bias and treatment effect.

Standards for reporting study conduct have changed over time. The majority of studies included in our review obtained evidence from trials published prior to 1990, before the publication and adoption of the CONSORT reporting standards. To be in conformance with these standards, published study results are more likely to reflect actual trial conduct in RCTs published after their dissemination. Even so, two recent meta-epidemiological studies evaluating more recently published trials continued to show problems with reporting. One study78 sampled trials published for a 1-month interval in 2011 in journals that subscribe to the CONSORT reporting standards and found that 78 percent were rated as unclear or insufficient to assess allocation concealment. Their attempt to contact authors for clarification to minimize misclassification yielded a poor response. A second study79 evaluated RCTs in top-rated orthopedic journals for a 4-year period (2006 to 2010) and found inadequate reporting to judge the approach to sequence generation and allocation concealment in approximately half the studies; however, they also showed some improvement as a function of increasingly later year of publication.

Studies differed in the instruments used to evaluate a bias and because of this, their approach to making the evaluation. For example, the Jadad scale does not provide an explicit question for allocation concealment, even though this instrument is known to otherwise be reliable. Therefore, earlier studies generally added items to the Jadad scale to address allocation concealment. Some of the more recent meta-epidemiological studies in our systematic review used other instruments (and different criteria) to assess risk of bias, most notably the risk-of-bias tool developed by the Cochrane Collaboration. The Cochrane tool continues to evolve and improve with respect to operationalizing criteria to adequately measure bias categories. A number of studies have evaluated the reliability and validity of the Cochrane tool and suggested improvements in the criteria and approach to assessing risk of bias in general.67, 69 These variations and ongoing improvements suggest that the different tools used to assess risk of bias are themselves a source of heterogeneity. Future research should attempt to establish consensus on the criteria for determining adequate, inadequate, and unclear status for the bias being evaluated.

Because this body of literature is primarily based on meta-epidemiological studies, it builds on multiple units of analysis (patients, trials, and meta-analyses). Each of these levels of combination has the potential for substantial heterogeneity. Many of the earlier studies combined trials or meta-analyses that examined different interventions, diseases, or outcomes. While this approach would increase the power of the analysis by increasing the sample size, the approach assumes that combining disparate trials would not negatively impact the estimate of the bias. Our results demonstrate that most of these sources of heterogeneity were not accounted for consistently in the meta-epidemiological studies and it could potentially obscure the relationship between a bias and treatment effect.

Further regarding patient-level heterogeneity, conclusions from meta-analyses about the absence of effect between the proportion of dropouts and treatment effect may be incorrect. Meta-epidemiological studies, by combining aggregate measures of dropouts at the meta-analysis level, may fail to account for variations within and between trials in which improved treatment effect and lower dropout rates were associated.30

Some of the more recent studies showed differential magnitude based on the type of outcome (mortality versus morbidity, objective vs. subjective) and intervention (drug versus nondrug, conventional versus complementary) categories. Some studies attempted to evaluate the impact of particular biases, adjusting for other factors, such as trial sample size, source of funding, and magnitude of effect (large versus small); these issues were studied infrequently and inconsistently and no consistent impact was observed. Further evaluation of the role of differing interventions, populations (diseases), outcomes, and other factors will be an important area to explore in future research.

Additional considerations that differed across studies and that may have caused accuracy and precision of results to differ include how comparisons were measured (ratio of odd ratios, difference in effect estimates, or some other approach) and approaches to modeling.

An additional limitation is the lack of evaluation of statistical power. Power calculations in this setting are challenging because of the hierarchical nature of the meta-epidemiological study design (patients within trials within meta-analyses within meta-epidemiological studies). The fact that meta-epidemiological studies may be underpowered was a motivation for the Bias in Randomised & Observational Studies (BRANDO) project (personal correspondence, Jonathan Sterne, 2012). If the meta-epidemiological studies are underpowered, nonsignificant findings may be because of lack of power, not lack of effect. Hempel et al.35 presented evidence and concluded that although bias components may explain some heterogeneity, the degree of heterogeneity due to other factors is key in parsing out the effect of bias. The authors concluded that most meta-epidemiological studies are underpowered to detect the effects of bias. Furthermore, the Hempel study was conducted on individual trials, rather than at the meta-epidemiological level as was most of our included evidence. Even with individual trial data, Hempel et al. were unable to clearly and consistently discern the impact of individual bias components across multiple datasets. One conclusion is that larger, carefully constructed datasets of individual trials must be assembled and analyzed to thoroughly understand the effect of bias as distinct from other sources of treatment effect heterogeneity. Our results should be viewed in light of this caveat.

Meta-analysis level heterogeneity in the types of biases in included studies and failure to account for potential interactions and confounding among various sources of bias may have resulted in an overstatement or understatement of the extent that bias influences treatment effect. Only 7 of 35 studies examined interactions between various sources of bias: Schulz et al.,22 Linde et al.,25 Nuesch et al.,48, 49 Wood et al.,45 Liu et al.,59 Hrobjartsson et al.,60 and Savovic et al.6, 62 For example, studies with inadequate allocation concealment may also be prone to problems with blinding. The meta-epidemiological studies also varied in the modeling approaches used to evaluate the potential relationship between bias and treatment effect, and it was often difficult to discern the exact specifications of the models that were fit. Thus, comparison across studies was difficult. The important consideration is that biases may be associated with each other and future research should attempt to disentangle possible relationships using appropriate statistical methods.

Finally, we attempted to evaluate the quality of meta-epidemiological or other included studies to understand whether the design, conduct, or analysis of these studies could have influenced whether they themselves found differences in treatment effects for biased primary trials. Our criteria focused on risk of bias (from selection of studies, adjustments for confounding, validity and reliability of bias measure), applicability (whether findings apply to other clinical areas), and precision (power calculations). Given the wide variability in study designs, populations, measures of risk of bias, and approaches to analyses, we were unable to discern patterns in treatment effect differences associated with the quality of the meta-epidemiological and other studies included as evidence.

## Specific Biases: Key Considerations

### Selection Bias: Sequence Generation and Allocation Concealment

We identified more studies evaluating allocation concealment than sequence generation as a means of adjusting for potential selection bias. Both biases showed a consistent trend toward exaggeration of treatment effect when these biases were present. However, differences reached statistical significance in less than half of the studies for allocation concealment and in very few for sequence generation. The magnitude of overestimation of the treatment effect was greatly variable across studies, ranging from 50 to 5 percent. Overall, our findings suggest that across studies inadequate sequence generation and allocation concealment may exaggerate the estimate of effect, but the magnitude varies considerably and evidence of precision is poor.

The studies evaluating the impact of allocation concealment and sequence generation bias were prone to all the challenges previously noted in this discussion, particularly with respect to the consistency of the bias definitions (and specific tools used to assess), the outcomes used to assess the impact of the bias, the year of trial publication, and other sources of heterogeneity (outcomes, interventions, populations, sample size, other characteristics). Future research in assessing the impact of allocation concealment and sequence generation on effect estimates would benefit from a more explicit description and presentation of the statistical modeling approach undertaken. For example, many studies did not clarify if all trials measured the outcome in the same direction (so that the odds ratios or difference in treatment effect showed the same direction of the effect of the intervention). As a further example, the factors included in the models should be clearly defined. Finally, assumptions about the model form should be made clear, such as whether the effect of a trial characteristic is assumed to be constant across meta-analyses, and evaluations of such assumptions should be conducted.16

### Confounding

Only two studies evaluated the effect of confounding.30, 50 Neither found a precise estimate of effect, but both focused on trials only. When imbalance in prognostic arms may occur by chance in trials, this is random error and therefore not related to bias; it may not be linked with treatment effect.

## Performance Bias: Fidelity to Protocol, Unintended Interventions or Cointerventions

Two studies evaluating four databases found inconsistent effects in magnitude, direction, and statistical significance for fidelity to protocol and unintended interventions.35, 50 Of the four databases, only one found a statistically significant difference in treatment effects as a result of compliance or cointerventions.

### Performance Bias: Patient/Caregiver or Provider Blinding

We found the evidence of an effect of either patient/caregiver or provider blinding to be inconsistent across studies. This, coupled with variation in the approach across studies, limits our reaching conclusions in relation to these potential protections against performance bias.

### Detection Bias: Assessor Blinding

We anticipated that although outcome assessment may be vulnerable to assessor bias in measuring any outcome, it would be particularly vulnerable when the outcome being measured is subjective. We found some compelling evidence that lack of assessor blinding could lead to exaggerated effects. Most notably, evidence of a larger effect from lack of assessor blinding was found in Hrobjartsson et al.60 who may have been better able to observe differences because the authors compared the effect within individual studies. Their subgroup findings, limited to studies with subjective outcomes, found more exaggerated differences. A second study measuring subjective outcomes (muscle strength) also found a significant and exaggerated effect across studies.59

However, our confidence in our conclusion is tempered by inconsistencies across the larger body of evidence; two large studies with multiple analyses did not find a consistent relationship, in significance or direction of effect. In Balk et al.30 results were stratified by clinical area, not by whether the outcome was measured subjectively or objectively. The appropriate role of the Hempel et al.35 study on our conclusions is more elusive because of different results across the four datasets. Effect estimates were not in a consistent direction, and only one of four separate datasets found a significant relationship; it was not the dataset limited to a subjective outcome (pain).

### Detection Bias: Valid Statistical Measures

Only two studies considered the role of valid statistical measures on treatment effect and their approach to measurement differed. Neither measured the validity of the statistical measures against a gold standard, such as an independent evaluation of the difference in the results based on an approach that would be recommended by methodological experts and the one that was used by the researchers. Instead, one relied on reviewers' general notions of the quality of the approach, and the second considered prespecification of the criteria for evaluating statistical significance and power. Therefore, we consider the evidence to be insufficient for reaching any conclusions.

## Performance/Detection Bias: Double Blinding

The empirical evidence was mixed in relation to supporting whether lack of double blinding significantly affects differences in the direction, size, or significance of outcomes in trials. However, our evaluation of double blinding could only be as good as the information presented in journal articles across a large number of studies. We found that not only did the definition of double blinding vary across studies (such as whether the combination that constituted the “double” included assessor, patient, and/or provider), but that the comparison categories were inconsistent as well (ranging from clearly not blinded to blinding unknown or not reported). We cannot know if the general lack of statistically significant association we found between blinding groups is partially due to vaguely described or different definitions used across studies.

Lack of double blinding, similar to lack of assessor blinding, was related to an exaggeration of the intervention effect estimates when subjective outcomes were estimated. These findings suggest that in circumstances that provide greater room for individual judgment or preferences, blinding is critical.

Lack of double blinding was also more likely to be related to significantly exaggerated treatment effect in studies that were limited to particular clinical topic areas (such as obstetrics, pharmaceutical trials, or homeopathy). This may imply that combining studies into large databases, while improving the power for statistical testing, may also be creating unmeasured error or “noise” because of this heterogeneity across studies; this may be less likely to affect more limited subject areas. We do not have sufficient data to support either this explanation or an alternative, that double blinding could be more important in those specific clinical areas.

Lastly, much of the evidence on this bias came from studies that relied on the same databases of trials or various combinations of a relatively small number of databases of trials. If studies included in these databases are inherently different from studies generally, then the results are not generalizable.

### Attrition Bias

The lack of precision in findings for attrition bias calls attention to issues of power, as discussed earlier in this section. Additionally, the empirical evidence on whether aspects of attrition bias influence treatment effect appears to be linked to the measures used. Most estimates of attrition yielded inconsistent and imprecise results. Measures of reporting (did the study provide the number and reasons for withdrawal and dropout for each group?28, 30, 61) and conduct (percentage of dropouts30 or dropouts under a prespecified threshold6, 50, 74) did not result in consistent or precise estimates of treatment effect. Similarly, studies focusing on a combination of reporting, conduct, and analysis that evaluated the effect of intention-to-treat analysis on treatment effect also found inconsistent estimate of effects with overlapping confidence intervals,23, 30, 50, 61, 64, 74 as did studies using the Cochrane risk-of-bias tool,52, 67 dichotomous but undefined measures of complete followup,25 or disclosure of withdrawals.47 One study collapsing “no” and “unclear” responses for exclusions reported imprecise estimates of effect of exclusions on treatment effect.22

Only one measure of attrition bias found precise estimates for differences in treatment effect: both studies that collapsed “yes” and “unclear” responses for exclusion found that meta-analyses with exclusions tend to have different treatment effects.39, 49 These effects may be more pronounced for meta-analyses with large treatment effects or with a high level of heterogeneity or for specific types of interventions.49

Meta-analyses of efficacy routinely evaluate whether studies have accounted for patient exclusions. The limited evidence from this analysis suggests focusing on measures of analysis of attrition, rather than reporting or study conduct alone.

The CONSORT extension for harms suggests that results for harms should also be analyzed based on intention-to-treat because such an approach maintains the original random assignment.80 Intention-to-treat may be the most conservative approach when evaluating superiority trials that test a null hypothesis of no difference between study arms. Meta-analysis of equivalence trials (that test a null hypothesis of a difference between study arms) may require a close examination of both per-protocol analysis and intention-to-treat analysis to ensure that the most conservative analysis is chosen.46

### Reporting Bias: Selective Outcome Reporting

The findings of studies on outcome reporting bias suggest that authors of systematic reviews should expect, unless otherwise confirmed, that every review is at risk of bias from selective outcome reporting in the original studies. Four of five approaches to measuring selective outcome reporting suggest a difference in treatment effect as a result of selective outcome reporting; no study using the Cochrane risk-of-bias tool consistently found effects. One of these four approaches (testing the effect of the proportion of trials contributing to the meta-analysis) holds limited relevance for prospective application to new reviews. The other three approaches to identify the extent of the risk (comparing protocols to publications, evaluating the association between statistical significance tests and extent of reporting, using a combination of inference and judgment in comparing outcomes from individual studies to outcomes in the body of evidence) can be applied to future systematic reviews but have significant constraints. All approaches require outreach to authors of included studies. Response rates from authors varied in five included studies from 11 percent to 90 percent. Other studies evaluating the overall risk of bias have found similarly low response rates.52 Another alternative, at least for trials, is to standardize data fields in registries such as ClinicalTrials.gov so that the required information is made public routinely, particularly if space limitations in journals constrain the complete reporting of outcomes. At the present time, existing data in ClinicalTrials.gov offer limited utility for evaluating selective outcome reporting.81

Each approach to address selective outcome reporting has constraints. Expanding searches to sidestep the potential bias from inadequate indexing (influenced by the choice of definitions by trialists) and including reviews of protocols could result in a vast expansion of the scope of work for systematic reviews; the gains from this expansion of scope of work remain unclear. Studies that evaluate the likelihood of full versus incomplete reporting based on statistical significance offer utility for assessing the prevalence of selective outcome reporting and its likely effect in aggregate. They do not offer a practical approach to assessing the risk of selective outcome reporting for individual studies. The ORBIT approach, which relies on a diversity of outcomes in the body of evidence to help identify holes in reporting for individual studies, may not work as well in relatively homogenous bodies of evidence that nonetheless may be at risk of selective outcome reporting (as, for instance, in a body of evidence on a single intervention supported by a single funder). As noted earlier, the task of classifying studies as high, low, or no risk of selective outcome reporting bias relies on inference and judgment; response rates from trial authors to validate these judgments are highly variable.

## Limitations of the Review Process

As noted by other studies evaluating the effect of bias,17 we may not have constructed efficient (highly sensitive and specific) search strategies because some eligible studies may not be indexed with the terms that were used in this systematic review. As a result, we may have missed other relevant studies. Additionally, we restricted our search to capture studies assessing bias within randomized trials. We excluded studies that focused solely on nonrandomized studies or compared nonrandomized studies with randomized studies.

We attempted to evaluate the quality of included studies. Our criteria focused on risk of bias (from selection of studies, adjustment for confounding, validity and reliability of bias measure), applicability (whether findings apply to other clinical areas), and precision (power calculations). Given the wide variability in study designs, populations, measures of risk of bias, and approaches to analyses, we were unable to discern patterns in outcomes associated with study quality.

## Research Gaps and Implications for Future Research

These findings may assist review teams in developing approaches to evaluating risk of bias and strength of evidence and support other methods development projects. Although empirical evidence should be the foundation for the methods used within systematic reviews, in relation to protection from bias, we cannot conclude that lack of a finding of a significant relationship implies that a relationship does not exist. Reviewers should consider the magnitude of potential effects of bias when interpreting effects (both direction and magnitude) in reviews and meta-analyses. Future research advancing systematic review methods needs to address the gaps we have identified in this review. Risk-of-bias assessments are considered the cornerstone of the four key factors affecting the grading of strength of evidence, and validation of the impact of these assessments remains key.

Future meta-epidemiological studies should not assume that differing interventions, outcomes, or populations (diseases) will not affect the magnitude of impact of the presence of biases on treatment effects. Although the magnitude and direction of an effect are important for drawing conclusions from a review, for future meta-epidemiological studies to have the most impact on future trial design and implementation, these studies will need to be adequately powered to be able to account for various sources of heterogeneity. Power calculations would have to take into account the intra-cluster correlations at the trial and meta-analysis levels, akin to the approach taken to design a cluster-randomized trial with two levels of clustering, for example, for the design of a cluster-randomized trial of patients within clinician within hospital. Current meta-epidemiological studies could provide a range of correlation estimates with which to conduct these power calculations.

Future meta-epidemiologic studies evaluating the impact of these biases should have access to and build on a database of existing trials and observational studies such as the one developed by the BRANDO project. Such future studies would thus be conducted with the unit of analysis equal to the individual trial or observational study, rather than built from meta-analyses or at the meta-epidemiological study level. Future studies would increase their reliability by using methods that control for consistency in evaluations across trials, beyond differences in trial conduct. For example, the “noise” in an analysis could be lessened by limiting the risk of bias assessment to one instrument implemented through a dual review process, distinguishing between information that is not reported and not adequately performed, including only new studies that were subject to stricter reporting standards, and not attempting to evaluate complex concepts such as double blinding, where meeting the standard may not be consistent across studies.

Future studies in this area should also account for the potential for patient-level heterogeneity and ecological fallacy. Such fallacy can result from using average patient-level values at the study level, thereby ignoring patient-level variation; as such, meta-analysis of individual patient-data may be required.

Lastly, future studies should focus, when possible, on trials published after the dissemination of reporting standards. Trials or meta-analyses published after 1996 are less likely to have limitations in reporting; assessment of the presence or absence of the bias is more likely to be valid as a result.

## Implications for Reviewers

Of greatest concern are the implications of our findings for systematic reviewers. Although we only found statistically significant differences by studies employing a minority of protections against bias, we do not conclude that reviewers should abandon these evaluations. We discussed a number of considerations that would have resulted in imprecision and noise in study findings, so generally we conclude that additional evidence and evaluation are needed.

In those instances where we did find relatively consistent and precise differences in effect (allocation concealment, sequence generation, lack of assessor blinding in evaluating subjective outcomes, and selective outcome reporting), reviewers should consider being more cautious in rating risk of bias in relation to these concerns. Reviewers may also consider the lack of these protections against potential biases on treatment effect by conducting sensitivity analyses prior to integrating estimates from studies with these concerns in their strength of evidence grades. Lastly, of particular interest were findings from the BRANDO study that failings in study conduct concerning two biases increased the size of the difference in the effect estimate beyond the additive effect of each of the individual biases.6 This may imply a value in more cautiously evaluating studies that lack protections for multiple sources of bias, including biases without consistent or precise evidence of having an individual effect.