# Background

Epidemiological theory supports that there is a relationship between various types of bias in study conduct and the observed effect.1 Bias may occur in selection of the sample, detection of treatment effects, performance of the study, and reporting of outcomes, each of which may increase the size of the observed effect. Because of this, systematic reviews evaluate the risk of bias of each included study. However, the empirical evidence supporting the theoretical relationships has been mixed or has not yet been tested. Prior reviews have attempted to summarize and compare the empirical evidence, but they are either outdated or not exhaustive. West et al. (2002),2 focusing on systems to rate the quality (risk of bias) of studies, presented some empirical evidence concerning the relationship between bias and treatment effect, as did Deeks et al. (2003)3 comparing randomized and nonrandomized studies and Song et al. (2000)4 limited to publication and related biases. In reviewing the Cochrane Handbook, we found, that only empirical evaluations supporting concern about each of the potential sources of bias were cited, while studies that showed no relationship were not.5 The recent BRANDO study (Bias in Randomized and Observational Studies) analyzed combined data from a large number of trials included in seven earlier methodological evaluations with the aim of further quantifying the effect of biases and other flaws in trial conduct and their effect on outcomes.6 The empirical results from the BRANDO study are included in this review. BRANDO did not include a systematic review of the earlier evaluations that had similar or related goals (personal correspondence, Jonathan Sterne, 2012).

## Key Questions

The goal of this review was to comprehensively and systematically review and compare empirical evaluations of the effect of specific types of bias on effect estimates of outcomes among studies reported in systematic reviews. The types of biases and approaches that trials may use to adjust for each bias are presented in Table 1; this classification draws primarily from the Cochrane Handbook for Systematic Reviews,5 but also draws on material from other sources, including Hernan et al., (2004),7 Rothman et al., (2003),1 and Viswanathan and Berkman (2012).8 They include the potential sources of bias that are commonly of concern among systematic reviewers who are evaluating the risk of bias in individual studies. We note that instruments designed to identify risk of bias in individual studies differ in their approach, including the specific questions used for measurement. We did not restrict this analysis to particular approaches to measurement of biases and we included all measures, specifying the exact question where provided.

Table 1 Potential sources of bias in studies (threats to internal validity) and approaches used to address specific biases

Type of Bias | Description | Approaches to Addressing the Bias
Selection bias at baseline including confounding | Systematic differences between baseline characteristics of the groups that are compared as a result of non-random enrolment in the study. Includes confounding that occurs when patient prognostic characteristics, such as disease severity or comorbidity, influence both treatment source and outcomes. Confounders are the common cause for intervention and exposure; they occur before exposure. Confounding can occur from self-selection of treatments or physician-directed selection of treatments. | 1. Adequate sequence generation (randomization); 2. Allocation concealment; 3. Confounding in RCTs typically addressed through randomization; in RCTs with randomization issues, confounding accounted for through analysis
Performance bias | Systematic differences in the care provided to participants and protocol deviation. Examples include contamination of the control group with the exposure or intervention, unbalanced provision of additional interventions or co-interventions, difference in co-interventions, and inadequate blinding of providers and participants. | 1. Fidelity to the protocol; 2. Avoidance of unintended interventions or co-interventions; 3. Patient/caregiver blinding; 4. Clinician/provider blinding
Detection bias | Systematic differences in outcomes assessment among groups being compared, including systematic misclassification of the exposure or intervention, covariates, or outcomes because of variable definitions and timing, diagnostic thresholds, recall from memory, inadequate assessor blinding, and faulty measurement techniques, including a lack of valid and reliable measures. Erroneous statistical analysis might also affect the validity of effect estimates. | 1. Outcome assessor blinding; 2. Data analyst blinding; 3. Appropriate statistical methods
Attrition bias | Systematic differences in the loss of participants from the study and how they are accounted for in the results (e.g., incomplete followup, differential attrition). Bias resulting from incomplete outcomes assessment. Bias from missing data can result in selection bias during the course of the study. | 1. Intention-to-treat analysis; 2. Accounting for dropouts; 3. Obtaining complete data
Reporting bias | Systematic differences between reported and unreported findings (e.g., differential reporting of outcomes or harms, incomplete reporting of prespecified study findings). | 1. Complete reporting of all prespecified outcomes

Abbreviations: RCT = randomized controlled trials.

Our initial key questions were the following:

1. What sources of bias have been evaluated empirically for their impact on study effect estimates? Sources of bias include selection bias and confounding, performance bias, attrition bias, detection bias, and selective outcome reporting bias. For the purposes of this review, we do not include publication bias.
2. What evidence exists that these sources of bias influence effect estimates?

Input from a Technical Expert Panel advised the study team to further refine the analysis in several important ways. These refinements are reflected in revised key questions and include the following: limit the review to randomized controlled trials (RCTs) because we would be unlikely to find meta-analyses or meta-epidemiological studies focusing on examining risk of bias in observational studies; highlight evidence of the effect of one source of bias, adjusting for other biases and interactions between sources of bias; and distinguish between evidence that was obtained from meta-epidemiological studies and other designs.

Our revised key questions are as follows:

1. What sources of risk of bias in the design and conduct of RCTs have been evaluated empirically for their impact on study effect estimates?
  We include the sources of bias that are most likely to be of concern in an RCT: selection, confounding, performance, detection, attrition, and outcome reporting.
2. What is the evidence that selection, confounding, performance, detection, attrition, and selective outcome reporting bias influence effect estimates? Findings will include the following:
  a. If results measuring one source of bias adjust for the effect of one or more additional biases or the interaction between sources of bias.
  b. If results differ by whether analyses were conducted using particular analytic approaches or when limited to specific types of diseases, interventions, or outcomes.

For consistency and clarity throughout the report, we refer to our analyses in this report as a review, the meta-epidemiological or other empirical publications that we reviewed as studies, and the individual RCTs on which they were based as trials.