# Detailed Study Characteristics

Table D-1 Characteristics of all included studies

Table D-2 List of interventions, diseases, outcomes and factors controlled for in the analyses

Table D-3 Allocation concealment definitions

Table D-4 Sequence generation definitions

## References for Appendix D

1 Schulz KF, Chalmers I, Hayes RJ, et al. Empirical evidence of bias. Dimensions of methodological quality associated with estimates of treatment effects in controlled trials. JAMA. 1995;273(5):408-12. [pmid: 7823387].
2 Juni P, Witschi A, Bloch R, et al. The hazards of scoring the quality of clinical trials for meta-analysis. JAMA. 1999;282(11):1054-60. [pmid: 10493204].
3 Nurmohamed MT, Rosendaal FR, Buller HR, et al. Low-molecular-weight heparin versus standard heparin in general and orthopaedic surgery: a meta-analysis. Lancet. Jul. 18. 1992;340(8812):152-6. [pmid: 1352573].
4 Linde K, Scholz M, Ramirez G, et al. Impact of study quality on outcome in placebo-controlled trials of homeopathy. J Clin Epidemiol. 1999;52(7):631-6. [pmid: 10391656].
5 Tang JL. Weighting bias in meta-analysis of binary outcomes. J Clin Epidemiol. 2000;53(11):1130-6. [pmid: 11106886].
6 Moher D, Cook DJ, Jadad AR, et al. Assessing the quality of reports of randomised trials: implications for the conduct of meta-analyses. Health Technol Assess. 1999;3(12):i-iv. 1. 98. [pmid: 10374081].
7 Moher D, Pham B, Jones A, et al. Does quality of reports of randomised trials affect estimates of intervention efficacy reported in meta-analyses?. Lancet. 1998;352(9128):609-13. [pmid: 9746022].
8 Kjaergard LL, Villumsen J, Gluud C. Reported methodologic quality and discrepancies between large and small randomized trials in meta-analyses. Ann Intern Med. 2001;135(11):982-9. [pmid: 11730399].
9 Balk EM, Bonis PA, Moskowitz H, et al. Correlation of quality measures with estimates of treatment effect in meta-analyses of randomized controlled trials. JAMA. 2002;287(22):2973-82. [pmid: 12052127].
10 Clifford TJ, Barrowman NJ, Moher D. Funding source, trial outcome and reporting quality: are they related? Results of a pilot study. BMC Health Services Research. 2002;2(1):18. [pmid: 12213183].
11 Sterne JA, Juni P, Schulz KF, et al. Statistical methods for assessing the influence of study characteristics on treatment effects in ‘meta-epidemiological’ research. Stat Med. 2002;21(11):1513-24. [pmid: 12111917].
12 Als-Nielsen B, Chen W, Gluud C, et al. Association of funding and conclusions in randomized drug trials: a reflection of treatment effect or adverse events?. JAMA. 2003;290(7):921-8. [pmid: 12928469].
13 Egger M, Juni P, Bartlett C, et al. How important are comprehensive literature searches and the assessment of trial quality in systematic reviews? Empirical study. Health Technol Assess. 2003;7(1):1-76. [pmid: 12583822].
14 Chan AW, Hrobjartsson A, Haahr MT, et al. Empirical evidence for selective reporting of outcomes in randomized trials: comparison of protocols to published articles. JAMA. 2004;291(20):2457-65. [pmid: 15161896].
15 Chan AW, Krleza-Jeric K, Schmid I, et al. Outcome reporting bias in randomized trials funded by the Canadian Institutes of Health Research. CMAJ. 2004;171(7):735-40. [pmid: 15451835].
16 Kyzas PA, Loizou KT, Ioannidis JP. Selective reporting biases in cancer prognostic factor studies. J Natl Cancer Inst. 2005;97(14):1043-55. [pmid: 16030302].
17 Tierney JF, Stewart LA. Investigating patient exclusion bias in meta-analysis. Int J Epidemiol. 2005;34(1):79-87. [pmid: 15561753].
18 Derry CJ, Derry S, McQuay HJ, et al. Systematic review of systematic reviews of acupuncture published 1996-2005. Clin Med. 2006;6(4):381-6. [pmid: 16956145].
19 Mohammed S, Goodacre S. Intravenous and nebulised magnesium sulphate for acute asthma: systematic review and meta-analysis. Emerg Med J. Dec. 2007;24(12):823-30. [pmid: 18029512].
20 Pildal J, Hrobjartsson A, Jorgensen KJ, et al. Impact of allocation concealment on conclusions drawn from meta-analyses of randomized trials. Int J Epidemiol. 2007;36(4):847-57. [pmid: 17517809].
21 Relevo R, Balshem H. Finding evidence for comparing medical interventions: AHRQ and the Effective Health Care Program. J Clin Epidemiol. Nov. 2011;64(11):1168-77. [pmid: 21684115].
22 Fenwick J, Needleman IG, Moles DR. The effect of bias on the magnitude of clinical outcomes in periodontology: a pilot study. J Clin Periodontol. 2008;35(9):775-82. [pmid: 18840153].
23 Wood L, Egger M, Gluud LL, et al. Empirical evidence of bias in treatment effect estimates in controlled trials with different interventions and outcomes: meta-epidemiological study. BMJ. 2008;336(7644):601-5. [pmid: 18316340].
24 Wartenberg D. Residential magnetic fields and childhood leukemia: a meta-analysis. Am J Public Health. 1998;88(12):1787-94. [pmid: 9842375].
25 Feng J, Wan G, Zhu X, et al. The apolipoprotein e (APOE) gene and the risk of diabetic nephropathy (DN): A meta-analysis in East Asian populations. Asian Biomedicine. 2010;4(2):329-35.
26 Treadwell J, Uhl S, Tipton K, et al. Assessing Equivalence and Noninferiority. Methods Research Report. (Prepared by the EPC Workgroup under Contract No. 290-2007-10063.) AHRQ Publication No. 12-EHC045-EF. Rockville, MD. Agency for Healthcare Research and Quality. June. 2012. www.effectivehealthcare.ahrq.gov.
27 Inaba Y, Chen JA, Mehta N, et al. Impact of single or multicentre study design on the results of trials examining the efficacy of adjunctive devices to prevent distal embolisation during acute myocardial infarction. Eurointervention. 2009;5(3):375-83. [pmid: 19736164].
28 Nuesch E, Trelle S, Reichenbach S, et al. The effects of excluding patients from the analysis in randomised controlled trials: meta-epidemiological study. BMJ. 2009;339:b3244. [pmid: 19736281].
29 Nuesch E, Reichenbach S, Trelle S, et al. The importance of allocation concealment and patient blinding in osteoarthritis trials: a meta-epidemiologic study. Arthritis Rheum. 2009;61(12):1633-41. [pmid: 19950329].
30 van Tulder MW, Suttorp M, Morton S, et al. Empirical evidence of an association between internal validity and effect size in randomized controlled trials of low-back pain. Spine (Phila Pa 1976). Jul. 15. 2009;34(16):1685-92. [pmid: 19770609].
31 Dwan K, Gamble C, Kolamunnage-Dona R, et al. Assessing the potential for outcome reporting bias in a review: a tutorial. Trials. [Electronic Resource]. 2010;11:52. [pmid: 20462436].
32 Higgins JPT, Green S, editors. Cochrane Handbook for Systematic Reviews of Interventions Version 5.0.1. [updated September 2008]. The Cochrane Collaboration. 2008.
33 Kirkham JJ, Dwan KM, Altman DG, et al. The impact of outcome reporting bias in randomised controlled trials on a cohort of systematic reviews. BMJ. 2010;340:c365. [pmid: 20156912].
34 Hartling L, Bond K, Vandermeer B, et al. Applying the risk of bias tool in a systematic review of combination long-acting beta-agonists and inhaled corticosteroids for persistent asthma. [Review]. PLoS ONE. [Electronic Resource]. 2011;6(2):e17242. [pmid: 21390219].
35 Hempel S, Miles J, Suttorp M, et al. Detection of Associations between Trial Quality and Effect Sizes. Methods Research Report. Prepared by the Southern California Evidence-based Practice Center under Contract No. 290-2007-10062-I AHRQ Publication No. 12-EHC010-EF. Rockville, MD. Agency for Healthcare Research and Quality. January. 2012.
36 Hempel S, Suttorp MJ, Miles JNV, et al. Empirical Evidence of Associations Between Trial Quality and Effect Sizes. Methods Research Report. (Prepared by the Southern California Evidence-based Practice Center under Contract No. 290-2007-10062-I) AHRQ Publication No. 11-EHC045-EF. Rockville, MD. Agency for Healthcare Research and Quality. June. 2011. http://effectivehealthcare.ahrq.gov.
37 Herbison P, Hay-Smith J, Gillespie WJ. Adjustment of meta-analyses on the basis of quality scores should be abandoned. [Review] [60 refs]. J Clin Epidemiol. 2006;59(12):1249-56. [pmid: 17098567].
38 Herbison P, Hay-Smith J, Gillespie WJ. Different methods of allocation to groups in randomized trials are associated with different levels of bias. A meta-epidemiological study. J Clin Epidemiol. 2011;64(10):1070-5. [pmid: 21474279].
39 Liu CJ, LaValley M, Latham NK. Do unblinded assessors bias muscle strength outcomes in randomized controlled trials of progressive resistance strength training in older adults?. Am J Phys Med Rehabil. Mar. 2011;90(3):190-6. [pmid: 21173683].
40 Hróbjartsson A, Thomsen AS, Emanuelsson F, et al. Observer bias in randomised clinical trials with binary outcomes: systematic review of trials with both blinded and non-blinded outcome assessors. BMJ. 2012;344:e1119. [pmid: 22371859].
41 Mhaskar R, Djulbegovic B, Magazin A, et al. Published methodological quality of randomized controlled trials does not reflect the actual quality assessed in protocols. J Clin Epidemiol. Jun. 2012;65(6):602-9. [pmid: 22424985].
42 Savovic J, Jones H, Altman D, et al. Influence of reported study design characteristics on intervention effect estimates from randomised controlled trials: combined analysis of meta-epidemiological studies. Health Technol Assess. Sep. 2012;16(35):1-82. [pmid: 22989478].
43 Savovic J, Jones HE, Altman DG, et al. Influence of reported study design characteristics on intervention effect estimates from randomized, controlled trials. Ann Intern Med. Sep. 18. 2012;157(6):429-38. [pmid: 22945832].
44 Als-Nielsen B, Chen W, Gluud LL, et al. Are trial size and reported methodological quality associated with treatment effects?. Program & Abstract Book, 12th Cochrane Colloquium. 2004;2004:102-3.
45 Siersma V, Als-Nielsen B, Chen W, et al. Multivariable modelling for meta-epidemiological assessment of the association between trial quality and treatment effects estimated in randomized clinical trials. Stat.Med. 2007;26(14):2745-58. [pmid: 17117373].
46 Contopoulos-Ioannidis DG, Gilbody SM, Trikalinos TA, et al. Comparison of large versus smaller randomized trials for mental health-related interventions. Am J Psychiatry. Mar. 2005;162(3):578-84. [pmid: 15741476].
47 Linde K, Ramirez G, Mulrow CD, et al. St John's wort for depression--an overview and meta-analysis of randomised clinical trials. BMJ. Aug. 3. 1996;313(7052):253-8. [pmid: 8704532].
48 Lim B, Manheimer E, Lao L, et al. Acupuncture for treatment of irritable bowel syndrome. Cochrane Database Syst Rev. 2006;(4):CD005111. [pmid: 17054239].
49 Palma S, Delgado-Rodriguez M. Assessment of publication bias in meta-analyses of cardiovascular diseases. J Epidemiol Community Health. Oct. 2005;59(10):864-9. [pmid: 16166360].
50 Savović J, Harris RJ, Wood L, et al. Development of a combined database for meta-epidemiological research. Research Synthesis Methods. 2010;1(3-4):212-25.
51 Lin DY. Cox regression analysis of multivariate failure time data: the marginal approach. Stat Med. 1994;13(21):2233-47. [pmid: 7846422].