# Excluded Full-Text Article List

1 Adams AS, Soumerai SB, Lomas J, et al. Evidence of self-report bias in assessing adherence to guidelines. [Review] [28 refs]. Int J Qual Health Care. 1999;11(3):187-92. [pmid: 10435838].
2 Alexander DD, Mink PJ, Cushing CA, et al. A review and meta-analysis of prospective studies of red and processed meat intake and prostate cancer. [Review]. Nutrition Journal. 2010;9:50. [pmid: 21044319].
3 Anderson CA, Shibuya A, Ihori N, et al. Violent video game effects on aggression, empathy, and prosocial behavior in eastern and western countries: a meta-analytic review. [Review] [79 refs]. Psychol Bull. 2010;136(2):151-73. [pmid: 20192553].
4 Baird DD, Weinberg CR, Rowland AS. Reporting errors in time-to-pregnancy data collected with a short questionnaire. Impact on power and estimation of fecundability ratios. Am J Epidemiol. 1991;133(12):1282-90. [pmid: 2063836].
5 Baldi I, Ponti A, Zanetti R, et al. The impact of record-linkage bias in the Cox model. J Eval Clin Pract. 2010;16(1):92-6. [pmid: 20367819].
6 Barden J, Derry S, McQuay HJ, et al. Bias from industry trial funding? A framework, a suggested approach, and a negative result. Pain. 2006;121(3):207-18. [pmid: 16495012].
7 Baron G, Ravaud P, Samson A, et al. Missing data in randomized controlled trials of rheumatoid arthritis with radiographic outcomes: a simulation study. Arthritis Rheum. 2008;59(1):25-31. [pmid: 18163406].
8 Barone BB, Yeh HC, Snyder CF, et al. Postoperative mortality in cancer patients with preexisting diabetes: systematic review and meta-analysis. [Review] [39 refs]. Diabetes Care. 2010;33(4):931-9. [pmid: 20351229].
9 Bassler D, Briel M, Montori VM, et al. Stopping randomized trials early for benefit and estimation of treatment effects: systematic review and meta-regression analysis. [Review] [22 refs]. JAMA. 2010;303(12):1180-7. [pmid: 20332404].
10 Bassler D, Ferreira-Gonzalez I, Briel M, et al. Systematic reviewers neglect bias that results from trials stopped early for benefit. [Review] [9 refs]. J Clin Epidemiol. 2007;60(9):869-73. [pmid: 17689802].
11 Berard A, Andreu N, Tetrault J, et al. Reliability of Chalmers' scale to assess quality in meta-analyses on pharmacological treatments for osteoporosis. Ann Epidemiol. 2000;10(8):498-503. [pmid: 11118928].
12 Biondi-Zoccai GG, Lotrionte M, Abbate A, et al. Compliance with QUOROM and quality of reporting of overlapping meta-analyses on the role of acetylcysteine in the prevention of contrast associated nephropathy: case study. [Review] [43 refs]. BMJ. 2006;332(7535):202-9. [pmid: 16415336].
13 Bjordal JM. A quantitative study of bias in systematic reviews. Advances in Physiotherapy. 2003;5(2):83-96.
14 Boccia S, De FE, Galli P, et al. A systematic review evaluating the methodological aspects of meta-analyses of genetic association studies in cancer research. Eur J Epidemiol. 2010;25(11):765-75. [pmid: 20830507].
15 Boyer K, Wies J, Turkelson CM. Effects of bias on the results of diagnostic studies of carpal tunnel syndrome. [Review] [41 refs]. Journal of Hand Surgery - American Volume. 2009;34(6):1006-13. [pmid: 19446966].
16 Braunholtz DA, Edwards SJ, Lilford RJ. Are randomized clinical trials good for us (in the short term)? Evidence for a “trial effect”. [Review] [26 refs]. J Clin Epidemiol. 2001;54(3):217-24. [pmid: 11223318].
17 Briel M, Lane M, Montori VM, et al. Stopping randomized trials early for benefit: a protocol of the Study Of Trial Policy Of Interim Truncation-2 (STOPIT-2). Trials. [Electronic Resource]. 2009;10:49. [pmid: 19580665].
18 Brooks JM, Fang G. Interpreting treatment-effect estimates with heterogeneity and choice: simulation model results. Clin Ther. 2009;31(4):902-19. [pmid: 19446162].
19 Brunoni AR, Amadera J, Berbel B, et al. A systematic review on reporting and assessment of adverse effects associated with transcranial direct current stimulation. International Journal of Neuropsychopharmacology. 2011;14(8):1133-45. [pmid: 21320389].
20 Canter PH, Ernst E. Sources of bias in reviews of spinal manipulation for back pain. Wi_n Klin Wochenschr. 2005;117(9-10):333-41. [pmid: 15989112].
21 Carpenter JR, Schwarzer G, Rucker G, et al. Empirical evaluation showed that the Copas selection model provided a useful summary in 80% of meta-analyses. J Clin Epidemiol. 2009;62(6):624-31. [pmid: 19282148].
22 Chootrakool H, Shi JQ, Yue R. Meta-analysis and sensitivity analysis for multi-arm trials with selection bias. Stat Med. 2011;30(11):1183-98. [pmid: 21538449].
23 Chou R, Aronson N, Atkins D, et al. AHRQ series paper 4: assessing harms when comparing medical interventions: AHRQ and the effective health-care program. [Review] [81 refs]. J Clin Epidemiol. 2010;63(5):502-12. [pmid: 18823754].
24 Colliver JA, Kucera K, Verhulst SJ. Meta-analysis of quasi-experimental research: are systematic narrative reviews indicated?. Med Educ. 2008;42(9):858-65. [pmid: 18715482].
25 Cook RJ, Wei W. Selection effects in randomized trials with count data. Stat Med. 2002;21(4):515-31. [pmid: 11836733].
26 Cronin AM, Vickers AJ. Statistical methods to correct for verification bias in diagnostic studies are inadequate when there are few false negatives: a simulation study. BMC Medical Research Methodology. 2008;8:75. [pmid: 19014457].
27 Curtin F, Elbourne D, Altman DG. Meta-analysis combining parallel and cross-over clinical trials. III: The issue of carry-over. Stat Med. 2002;21(15):2161-73. [pmid: 12210631].
28 De VC, Manzoli L, Marzuillo C, et al. A systematic review evaluating the potential for bias and the methodological quality of meta-analyses in vaccinology. [Review] [123 refs]. Vaccine. 2007;25(52):8794-806. [pmid: 18035456].
29 Dechartres A, Boutron I, Trinquart L, et al. Single-center trials show larger treatment effects than multicenter trials: evidence from a meta-epidemiologic study. Ann Intern Med. 2011;155(1):39-51. [pmid: 21727292].
30 Dechartres A, Charles P, Hopewell S, et al. Reviews assessing the quality or the reporting of randomized controlled trials are increasing over time but raised questions about how quality is assessed. [Review]. J Clin Epidemiol. 2011;64(2):136-44. [pmid: 20705426].
31 Deeks JJ, Dinnes JD, Amico R, et al. Evaluating non-randomised intervention studies. Health Technol Assess. 2003;7(27):iii-iix. 1. 173. [pmid: 14499048].
32 Devereaux PJ, Choi PT, El-Dika S, et al. An observational study found that authors of randomized controlled trials frequently use concealment of randomization and blinding, despite the failure to report these methods. J Clin Epidemiol. 2004;57(12):1232-6. [pmid: 15617948].
33 Diamond GA. Affirmative actions: can the discriminant accuracy of a test be determined in the face of selection bias?. Med Decis Making. 1991;11(1):48-56. [pmid: 2034075].
34 Dias S, McNamee R, Vail A. Bias in frequently reported analyses of subfertility trials. Stat Med. 2008;27(27):5605-19. [pmid: 18693327].
35 Doucet M, Sismondo S. Evaluating solutions to sponsorship bias. J Med Ethics. 2008;34(8):627-30. [pmid: 18667655].
36 Dwan K, Altman DG, Arnaiz JA, et al. Systematic review of the empirical evidence of study publication bias and outcome reporting bias. [Review] [45 refs]. PLoS ONE. [Electronic Resource]. 2008;3(8):e3081. [pmid: 18769481].
37 Engels EA, Schmid CH, Terrin N, et al. Heterogeneity and statistical significance in meta-analysis: an empirical study of 125 meta-analyses. [Review] [40 refs]. Stat Med. 2000;19(13):1707-28. [pmid: 10861773].
38 Fergusson D, Laupacis A, Salmi LR, et al. What should be included in meta-analyses? An exploration of methodological issues using the ISPOT meta-analyses. [Review] [33 refs]. Int J Technol Assess Health Care. 2000;16(4):1109-19. [pmid: 11155831].
39 Fisk WJ, Eliseeva EA, Mendell MJ. Association of residential dampness and mold with respiratory tract infections and bronchitis: a meta-analysis. [Review]. Environmental Health: A Global Access Science Source. 2010;9:72. [pmid: 21078183].
40 Gartlehner G, Morgan L, Thieda P, et al. The effect of study sponsorship on a systematically evaluated body of evidence of head-to-head trials was modest: secondary analysis of a systematic review. [Review] [72 refs]. J Clin Epidemiol. 2010;63(2):117-25. [pmid: 19880289].
41 Gluud LL. Bias in clinical intervention research. Am J Epidemiol. 2006;163(6):493-501. [pmid: 16443796].
42 Groenwold RH, Van Deursen AM, Hoes AW, et al. Poor quality of reporting confounding bias in observational intervention studies: a systematic review. [Review] [25 refs]. Ann Epidemiol. 2008;18(10):746-51. [pmid: 18693038].
43 Hahn S, Puffer S, Torgerson DJ, et al. Methodological bias in cluster randomised trials. [Review] [19 refs]. BMC Medical Research Methodology. 2005;5:10. [pmid: 15743523].
44 Hahn S, Williamson PR, Hutton JL, et al. Assessing the potential for bias in meta-analysis due to selective reporting of subgroup analyses within studies. Stat Med. 2000;19(24):3325-36. [pmid: 11122498].
45 Hawkins N, Scott DA, Woods BS, et al. No study left behind: a network meta-analysis in non-small-cell lung cancer demonstrating the importance of considering all relevant data. Value in Health. 2009;12(6):996-1003. [pmid: 19402854].
46 Hayden JA, Cote P, Bombardier C. Evaluation of the quality of prognosis studies in systematic reviews. Ann Intern Med. 2006;144(6):427-37. [pmid: 16549855].
47 Herbison P, Hay-Smith J, Gillespie WJ. Adjustment of meta-analyses on the basis of quality scores should be abandoned. [Review] [60 refs]. J Clin Epidemiol. 2006;59(12):1249-56. [pmid: 17098567].
48 Hewitt CE, Kumaravel B, Dumville JC, et al. Assessing the impact of attrition in randomized controlled trials. J Clin Epidemiol. 2010;63(11):1264-70. [pmid: 20573482].
49 Hunter PR. Household water treatment in developing countries: comparing different intervention types using meta-regression. Environmental Science & Technology. 2009;43(23):8991-7. [pmid: 19943678].
50 Ioannidis JP. Excess significance bias in the literature on brain volume abnormalities. Arch Gen Psychiatry. 2011;68(8):773-80. [pmid: 21464342].
51 Jadad AR, McQuay HJ. Meta-analyses to evaluate analgesic interventions: a systematic qualitative review of their methodology. [Review] [100 refs]. J Clin Epidemiol. 1996;49(2):235-43. [pmid: 8606325].
52 Jones R, Younie S, Macallister A, et al. A comparison of the scientific quality of publicly and privately funded randomized controlled drug trials. J Eval Clin Pract. 2010;16(6):1322-5. [pmid: 20738476].
53 Jorgensen AW, Maric KL, Tendal B, et al. Industry-supported meta-analyses compared with meta-analyses with non-profit or no support: differences in methodological quality and conclusions. BMC Medical Research Methodology. 2008;8:60. [pmid: 18782430].
54 Joseph L, Belisle P, Tamim H, et al. Selection bias found in interpreting analyses with missing data for the prehospital index for trauma. J Clin Epidemiol. 2004;57(2):147-53. [pmid: 15125624].
55 Juni P, Altman DG, Egger M. Systematic reviews in health care: Assessing the quality of controlled clinical trials. [Review] [37 refs]. BMJ. 2001;323(7303):42-6. [pmid: 11440947].
56 Juni P, Holenstein F, Sterne J, et al. Direction and impact of language bias in meta-analyses of controlled trials: Empirical study. Int J Epidemiol. 2002;31(1):115-23. [pmid: 11914306].
57 Katerndahl DA, Lawler WR. Variability in meta-analytic results concerning the value of cholesterol reduction in coronary heart disease: a meta-meta-analysis. Am J Epidemiol. 1999;149(5):429-41. [pmid: 10067902].
58 Keogh-Brown MR, Bachmann MO, Shepstone L, et al. Contamination in trials of educational interventions. [Review] [276 refs]. Health Technology Assessment (Winchester, England). 2007;11(43):iii-107. [pmid: 17935683].
59 Khan KS, Daya S, Jadad A. The importance of quality of primary studies in producing unbiased systematic reviews. Arch Intern Med. 1996;156(6):661-6. [pmid: 8629879].
60 Kilwein JH. Biases in medical literature. J Clin Pharm Ther. 1999;24(6):393-6. [pmid: 10651971].
61 Kondo N, Bessho H, Honda S, et al. Complement factor H Y402H variant and risk of age-related macular degeneration in Asians: a systematic review and meta-analysis. [Review]. Ophthalmology. 2011;118(2):339-44. [pmid: 20869121].
62 Kunz R, Neumayer HH, Khan KS. When small degrees of bias in randomized trials can mislead clinical decisions: an example of individualizing preventive treatment of upper gastrointestinal bleeding. Crit Care Med. 2002;30(7):1503-7. [pmid: 12130970].
63 Kunz R, Oxman AD. The unpredictability paradox: review of empirical comparisons of randomised and non-randomised clinical trials. BMJ. 1998;317(7167):1185-90. [pmid: 9794851].
64 Kunz R, Vist G, Oxman AD. Randomisation to protect against selection bias in healthcare trials. [Review] [113 refs][Update in Cochrane Database Syst Rev. 2011 4:MR000012; PMID: 21491415]. Cochrane Database of Systematic Reviews. 2007;2. MR000012. [pmid: 17443633].
65 Lee PN. Difficulties in assessing the relationship between passive smoking and lung cancer. [Review] [99 refs]. Stat Methods Med Res. 1998;7(2):137-63. [pmid: 9654639].
66 Lexchin J, Bero LA, Djulbegovic B, et al. Pharmaceutical industry sponsorship and research outcome and quality: systematic review. [Review] [26 refs]. BMJ. 2003;326(7400):1167-70. [pmid: 12775614].
67 Lijmer JG, Mol BW, Heisterkamp S, et al. Empirical evidence of design-related bias in studies of diagnostic tests. [Erratum appears in JAMA 2000 Apr 19;283(15):1963]. JAMA. 1999;282(11):1061-6. [pmid: 10493205].
68 Lin IF, Myunghee CP. Matched case-control data analysis with selection bias. Biometrics. 2001;57(4):1106-12. [pmid: 11764250].
69 Lo BW, Kyu HH, Jichici D, et al. Meta-analysis of randomized trials on first line and adjunctive levetiracetam. [Review]. Can J Neurol Sci. 2011;38(3):475-86. [pmid: 21515509].
70 MacLehose RR, Reeves BC, Harvey IM, et al. A systematic review of comparisons of effect sizes derived from randomised and non-randomised studies. [Review] [192 refs]. Health Technology Assessment (Winchester, England). 2000;4(34):1-154. [pmid: 11134917].
71 Marshall RJ. An empirical investigation of exposure measurement bias and its components in case-control studies. J Clin Epidemiol. 1999;52(6):547-50. [pmid: 10408994].
72 Marsoni S, Torri W, Taiana A, et al. Critical review of the quality and development of randomized clinical trials (RCTs) and their influence on the treatment of advanced epithelial ovarian cancer. Ann Oncol. 1990;1(5):343-50. [pmid: 2148106].
73 Matt GE, Navarro AM. What meta-analyses have and have not taught us about psychotherapy effects: a review and future directions. [Review] [114 refs]. Clin Psychol Rev. 1997;17(1):1-32. [pmid: 9125365].
74 Mhaskar R, Djulbegovic B, Magazin A, et al. Published methodological quality of randomized controlled trials does not reflect the actual quality assessed in protocols. J Clin Epidemiol. Jun. 2012;65(6):602-9. [pmid: 22424985].
75 Michaud S, Suzuki S, Harbarth S. Effect of design-related bias in studies of diagnostic tests for ventilator-associated pneumonia. [Review] [50 refs]. Am J Respir Crit Care Med. 2002;166(10):1320-5. [pmid: 12421741].
76 Miller F, Friede T, Kieser M. Blinded assessment of treatment effects utilizing information about the randomization block length. Stat Med. 2009;28(12):1690-706. [pmid: 19340815].
77 Moher D, Pham B, Klassen TP, et al. What contributions do languages other than English make on the results of meta-analyses?. J Clin Epidemiol. 2000;53(9):964-72. [pmid: 11004423].
78 Moher D, Pham B, Lawson ML, et al. The inclusion of reports of randomised trials published in languages other than English in systematic reviews. [Review] [72 refs]. Health Technology Assessment (Winchester, England). 2003;7(41):1-90. [pmid: 14670218].
79 Morissette K, Tricco AC, Horsley T, et al. Blinded versus unblinded assessments of risk of bias in studies included in a systematic review. Cochrane Database of Systematic Reviews: Reviews. 2011;(9). John Wiley & Sons. 2011.
80 Morris RK, Selman TJ, Zamora J, et al. Methodological quality of test accuracy studies included in systematic reviews in obstetrics and gynaecology: sources of bias. BMC Women's Health. 2011;11:7. [pmid: 21426545].
81 Naylor CD. Meta-analysis and the meta-epidemiology of clinical research. BMJ. Sep. 13. 1997;315(7109):617-9. [pmid: 9310553].
82 Odgaard-Jensen J, Vist GE, Timmer A, et al. Randomisation to protect against selection bias in healthcare trials. [Review][Update of Cochrane Database Syst Rev. 2007;(2):MR000012; PMID: 17443633]. Cochrane Database of Systematic Reviews. 2011;4. MR000012. [pmid: 21491415].
83 Oliveri RS, Wetterslev J, Gluud C. Transarterial (chemo) embolisation for unresectable hepatocellular carcinoma. [Review]. Cochrane Database of Systematic Reviews. 2011;3. CD004787. [pmid: 21412886].
84 Pereira TV, Ioannidis JP. Statistically significant meta-analyses of clinical trials have modest credibility and inflated effects. [Review]. J Clin Epidemiol. 2011;64(10):1060-9. [pmid: 21454050].
85 Perry M, Faes M, Reelick MF, et al. Studywise minimization: a treatment allocation method that improves balance among treatment groups and makes allocation unpredictable. J Clin Epidemiol. 2010;63(10):1118-22. [pmid: 20304606].
86 Peters J, Mengersen K. Selective reporting of adjusted estimates in observational epidemiology studies: reasons and implications for meta-analyses. [Review] [54 refs]. Eval Health Prof. 2008;31(4):370-89. [pmid: 19000980].
87 Petscavage JM, Richardson ML, Carr RB. Verification bias an underrecognized source of error in assessing the efficacy of medical imaging. Acad Radiol. 2011;18(3):343-6. [pmid: 21145764].
88 Pigott HE, Leventhal AM, Alter GS, et al. Efficacy and effectiveness of antidepressants: current status of research. [Review]. Psychother Psychosom. 2010;79(5):267-79. [pmid: 20616621].
89 Polit DF, Gillespie BM, Griffin R. Deliberate ignorance: a systematic review of blinding in nursing clinical trials. [Review]. Nurs Res. 2011;60(1):9-16. [pmid: 21127453].
90 Potter S, Brigic A, Whiting PF, et al. Reporting clinical outcomes of breast reconstruction: a systematic review. [Review]. J Natl Cancer Inst. 2011;103(1):31-46. [pmid: 21131574].
91 Rief W, Nestoriuc Y, von Lilienfeld-Toal A, et al. Differences in adverse effect reporting in placebo groups in SSRI and tricyclic antidepressant trials: a systematic review and meta-analysis. [Review] [185 refs]. Drug Saf. 2009;32(11):1041-56. [pmid: 19810776].
92 Rosner B, Willett WC, Spiegelman D. Correction of logistic regression relative risk estimates and confidence intervals for systematic within-person measurement error. Stat Med. 1071;8(9):1051-69. [pmid: 2799131].
93 Sampson M, Barrowman NJ, Moher D, et al. Should meta-analysts search Embase in addition to Medline?. J Clin Epidemiol. 2003;56(10):943-55. [pmid: 14568625].
94 Sanchez-Ramos L, Delke I, Zamora J, et al. Fetal fibronectin as a short-term predictor of preterm birth in symptomatic patients: a meta-analysis. [Review] [54 refs]. Obstet Gynecol. 2009;114(3):631-40. [pmid: 19701045].
95 Savard LA, Thompson DR, Clark AM. A meta-review of evidence on heart failure disease management programs: the challenges of describing and synthesizing evidence on complex interventions. [Review]. Trials. [Electronic Resource]. 2011;12:194. [pmid: 21846340].
96 Schmidt LM, Gotzsche PC. Of mites and men: reference bias in narrative review articles: a systematic review. [Review] [20 refs]. J Fam Pract. 2005;54(4):334-8. [pmid: 15833223].
97 Schulz KF, Chalmers I, Grimes DA, et al. Assessing the quality of randomization from reports of controlled trials published in obstetrics and gynecology journals. JAMA. 1994;272(2):125-8. [pmid: 8015122].
98 Schwarzer G, Antes G, Schumacher M. Inflation of type I error rate in two statistical tests for the detection of publication bias in meta-analyses with binary outcomes. Stat Med. 2002;21(17):2465-77. [pmid: 12205693].
99 Schwarzer G, Carpenter J, Rucker G. Empirical evaluation suggests Copas selection model preferable to trim-and-fill method for selection bias in meta-analysis. J Clin Epidemiol. 2010;63(3):282-8. [pmid: 19836925].
100 Shapiro S. Bias in the evaluation of low-magnitude associations: an empirical perspective. [Review] [32 refs]. Am J Epidemiol. 2000;151(10):939-45. [pmid: 10853631].
101 Shimada YJ, Shiota T. A meta-analysis and investigation for the source of bias of left ventricular volumes and function by three-dimensional echocardiography in comparison with magnetic resonance imaging. Am J Cardiol. 2011;107(1):126-38. [pmid: 21146700].
102 Song F, Parekh S, Hooper L, et al. Dissemination and publication of research findings: an updated review of related biases. [Review] [537 refs]. Health Technology Assessment (Winchester, England). 2001;14(8):iii-ixi. [pmid: 20181324].
103 Soonawala D, Middelburg RA, Egger M, et al. Efficacy of experimental treatments compared with standard treatments in non-inferiority trials: a meta-analysis of randomized controlled trials. Int J Epidemiol. 2010;39(6):1567-81. [pmid: 20837637].
104 Sterne JA, Egger M, Smith GD. Systematic reviews in health care: Investigating and dealing with publication and other biases in meta-analysis. [Review] [46 refs]. BMJ. 2001;323(7304):101-5. [pmid: 11451790].
105 Sterne JA, Gavaghan D, Egger M. Publication and related bias in meta-analysis: power of statistical tests and prevalence in the literature. J Clin Epidemiol. 2000;53(11):1119-29. [pmid: 11106885].
106 Sterne JA, Sutton AJ, Ioannidis JP, et al. Recommendations for examining and interpreting funnel plot asymmetry in meta-analyses of randomised controlled trials. BMJ. 2011;343:d4002. [pmid: 21784880].
107 Thompson S, Ekelund U, Jebb S, et al. A proposed method of bias adjustment for meta-analyses of published observational studies. Int J Epidemiol. 2011;40(3):765-77. [pmid: 21186183].
108 Tricco AC, Tetzlaff J, Pham B, et al. Non-Cochrane vs. Cochrane reviews were twice as likely to have positive conclusion statements: cross-sectional study. J Clin Epidemiol. 2009;62(4):380-6. [pmid: 19128940].
109 Tricco AC, Tetzlaff J, Sampson M, et al. Few systematic reviews exist documenting the extent of bias: a systematic review. [Review] [81 refs]. J Clin Epidemiol. 2008;61(5):422-34. [pmid: 18394534].
110 van TE, van de Pol RJ, Oostendorp RA, et al. Inter-rater reliability for measurement of passive physiological movements in lower extremity joints is generally low: a systematic review. [Review]. Journal of Physiotherapy. 2010;56(4):223-35. [pmid: 21091412].
111 Villar J, Mackey ME, Carroli G, et al. Meta-analyses in systematic reviews of randomized controlled trials in perinatal medicine: comparison of fixed and random effects models. Stat Med. 2001;20(23):3635-47. [pmid: 11746343].
112 Whiting P, Rutjes AW, Reitsma JB, et al. Sources of variation and bias in studies of diagnostic accuracy: a systematic review. [Review] [61 refs]. Ann Intern Med. 2004;140(3):189-202. [pmid: 14757617].
113 Williamson PR, Gamble C. Application and investigation of a bound for outcome reporting bias. Trials. 2007;8. 2007. Article Number: 9. Date of Publication: 06 Mar 2007.
114 Wilson DB, Lipsey MW. The role of method in treatment effectiveness research: evidence from meta-analysis. Psychological Methods. 2001;6(4):413-29. [pmid: 11778681].
115 Yengopal V, Mickenautsch S. Caries-preventive effect of resin-modified glass-ionomer cement (RM-GIC) versus composite resin: a quantitative systematic review. [Review]. European Archives of Paediatric Dentistry: Official Journal of the European Academy of Paediatric Dentistry. 2011;12(1):5-14. [pmid: 21299939].
116 Zeng Y, Duan X, Xu J, et al. TPO receptor agonist for chronic idiopathic thrombocytopenic purpura. [Review]. Cochrane Database of Systematic Reviews. 2011;(7). CD008235. [pmid: 21735426].
117 Turner EH, Knoepflmacher D, Shapley L. Publication bias in antipsychotic trials: an analysis of efficacy comparing the published literature to the US Food and Drug Administration database. PLoS Med. 2012;9(3):e1001189. [pmid: 22448149].