# Screening and Abstraction Forms

## B-1 Screening Forms

Level 1 Title and Abstract Screening Form
1. Does this study aim to assess the effect of bias (quality) on study effect size OR the validity of it conclusions?
  *note: quality is sometimes used as a synonym for bias
  ○ Yes/Maybe (include)
  ○ No (exclude)
2. Keep this paper as background
  ○ Yes
    Clear Response
3. Comment:

Full Text Screening Level 2
1. This citation should be excluded for the following reason:
  ○ Not in English (stop, submit)
  ○ Published before 1980 (stop, submit)
  ○ In vitro study only (stop, submit)
  ○ Medical tests only (screening, diagnosis, genetic testing) (stop, submit)
  ○ Simulation study only
  ○ None of the above (continue)
2. Does this paper evaluate one or more of the following: (check all that apply)
  ○ Selection bias- e.g. randomization, allocation, concealment, confounders (continue)
  ○ Attrition bias- e.g. dropout completeness of data (continue)
  ○ Detection bias- e.g. blinding outcome assessors, valid statistical methods (continue)
  ○ Performance bias- e.g. blinding participants and personnel, fidelity to protocol, unintended interventions (continue)
  ○ Reporting bias- e.g. selective outcome reporting (continue)
  ○ Publication bias only (stop and submit)
  ○ Other bias-identify (continue)
  ○ Other global bias (stop and exclude)
  ○ Wrong design: not designed to primarily look at effect of bias on effect size (stop and exclude)
3. Does this paper include the following outcomes:
  ○ Change in effect size and directions
  ○ Changes in estimates and variance
  ○ Estimates of heterogeneity ONLY
4. Is this paper useful for background?
  ○ Yes
5. Comments?

B-2 Full Text Abstraction Form – ID, Study chx, baseline chx section

RefID | First author's last name | Year | Publication title | Describe goal of the study | Name of disease(s) or condition(s) (list all) | Source(s) of bias examined (list all) | Outcomes selected (list outcomes, include details on how outcomes were selected) | Inclusion/exclusion Criteria (e.g, databases searched, dates of inclusion, type of clinical condition, size of meta-analysis, type of outcome [dichotomous outcomes required], level of heterogeneity)

Unit of analysis (study with MA nesting, or study without accounting for MA nesting) | N MA Eligible N Trial Eligible If N varies by clinical condition then list by clinical condition | N MA Included N Trial Included If N varies by clinical condition then list by clinical condition | N MA Analyzed N Trial Analyzed If N varies by clinical condition then list by clinical condition | Funding source | Add comments or specify “other” entries here (clarify which column the “other” entry belongs to)

B-3 Full Text Abstraction Form – Results section

RefID | First author's last name | Year | Publication title | Selection bias: adequate randomization (Yes/No) | Measurement of bias (Scale or question used) | Method of measurement (dual review or single review) | Inter-rater reliability | Statistics used to measure outcome (e.g., OR, Ratio of odd ratios) | Modeling approach (e.g, Bayesian) | Results 95% CI P value (Include any subanalyses) | Were the results stratified by clinical condition, outcome, or other variable? OR Did the study account for other sources of bias? (e.g., did the study consider blinding only for studies which had adequate allocation concealment?)

Selection bias: allocation concealment (Yes/No) | Measurement of bias (Scale or question used) | Method of measurement (dual review or single review) | Inter-rater reliability | Statistics used to measure outcome (e.g., OR, Ratio of odd ratios) | Modeling approach (e.g, Bayesian) | Results 95% CI P value | Were the results stratified by clinical condition, outcome, or other variable or did the study account for other sources of bias? (e.g., did the study consider blinding only for studies which had adequate allocation concealment?)

Selection bias: Confounders accounted for (Yes/No) | Measurement of bias (Scale or question used) | Method of measurement (dual review or single review) | Inter-rater reliability | Statistics used to measure outcome (e.g., OR, Ratio of odd ratios) | Modeling approach (e.g, Bayesian) | Results 95% CI P value | Were the results stratified by clinical condition, outcome, or other variable or did the study account for other sources of bias? (e.g., did the study consider blinding only for studies which had adequate allocation concealment?)

Detection bias: blinding (Yes/No) | Measurement of bias (Scale or question used) | Method of measurement (dual review or single review) | Inter-rater reliability | Statistics used to measure outcome (e.g., OR, Ratio of odd ratios) | Modeling approach (e.g, Bayesian) | Results 95% CI P value | Were the results stratified by clinical condition, outcome, or other variable or did the study account for other sources of bias? (e.g., did the study consider blinding only for studies which had adequate allocation concealment?)

Detection bias: Valid statistical methods (Yes/No) | Measurement of bias (Scale or question used) | Method of measurement (dual review or single review) | Inter-rater reliability | Statistics used to measure outcome (e.g., OR, Ratio of odd ratios) | Modeling approach (e.g, Bayesian) | Results 95% CI P value | Were the results stratified by clinical condition, outcome, or other variable or did the study account for other sources of bias? (e.g., did the study consider blinding only for studies which had adequate allocation concealment?)

Performance bias: fidelity to protocol (Yes/No) | Measurement of bias (Scale or question used) | Method of measurement (dual review or single review) | Inter-rater reliability | Statistics used to measure outcome (e.g., OR, Ratio of odd ratios) | Modeling approach (e.g, Bayesian) | Results 95% CI P value | Were the results stratified by clinical condition, outcome, or other variable or did the study account for other sources of bias? (e.g., did the study consider blinding only for studies which had adequate allocation concealment?)

Performance bias: unintended interventions or co-interventions (Yes/No) | Measurement of bias (Scale or question used) | Method of measurement (dual review or single review) | Inter-rater reliability | Statistics used to measure outcome (e.g., OR, Ratio of odd ratios) | Modeling approach (e.g, Bayesian) | Results 95% CI P value | Were the results stratified by clinical condition, outcome, or other variable or did the study account for other sources of bias? (e.g., did the study consider blinding only for studies which had adequate allocation concealment?)

Reporting bias: selective outcome reporting (Yes/No) | Measurement of bias (Scale or question used) | Method of measurement (dual review or single review) Inter-rater reliability Statistics used to measure outcome (e.g., OR, Ratio of odd ratios) Modeling approach (e.g., Bayesian) Results 95% CI P value Were the results stratified by clinical condition, outcome, or other variable or did the study account for other sources of bias? (e.g., did the study consider blinding only for studies which had adequate allocation concealment?) Attrition bias: ITT; dropouts; attrition bias; completeness of data (lumped together) (Yes/No) Measurement of bias (Scale or question used) Method of measurement (dual review or single review) Inter-rater reliability Statistics used to measure outcome (e.g., OR, Ratio of odd ratios) Modeling approach (e.g., Bayesian) Results 95% CI P value Were the results stratified by clinical condition, outcome, or other variable or did the study account for other sources of bias? (e.g., did the study consider blinding only for studies which had adequate allocation concealment?) Other bias (Describe): Multicentre study; study country; etc. Measurement of bias (Scale or question used) Inter-rater reliability Statistics used to measure outcome (e.g., OR, Ratio of odd ratios) Modeling approach (e.g, Bayesian) Results 95% CI P value Were the results stratified by clinical condition, outcome, or other variable or did the study account for other sources of bias? (e.g., did the study consider blinding only for studies which had adequate allocation concealment?) Comments

B-3 Full Text Abstraction Form – Quality questions + AMSTAR section

RefID | First author's last name | Year | Trial name (if applicable)

Were studies selected by a census? If no, how was the sample selected? (options: Randomly, purposefully, or unknown). Describe. | Selection bias: Did the study account for confounding or interaction among sources of bias? (Y/N) | Detection bias: Did the study use dichotomous measures for high vs. low quality? (Y/N) | Detection bias: If the study used dichotomous measures for high vs. low quality, how was the threshold determined? | Detection bias: IRR of risk of bias measure | Detection bias: validity of risk of bias measure | Precision: How was sample size calculated?

Do the findings of this meta-epidemiological study apply to multiple clinical areas? | Analysis: did the study account for duplication of trials? | IS THIS STUDY A SYSTEMATIC REVIEW | Was an ‘a priori’ design provided? The research question and inclusion criteria should be established before the conduct of the review. | Was there duplicate study selection and data extraction? There should be at least two independent data extractors and a consensus procedure for disagreements should be in place.

Was a comprehensive literature search performed? At least two electronic sources should be searched. The report must include years and databases used (e.g. Central, EMBASE, and MEDLINE). Key words and/or MESH terms must be stated and where feasible the search strategy should be provided. All searches should be supplemented by consulting current contents, reviews, textbooks, specialized registers, or experts in the particular field of study, and by reviewing the references in the studies found. | Was the status of publication (i.e. grey literature) used as an inclusion criterion? The authors should state that they searched for reports regardless of their publication type. The authors should state whether or not they excluded any reports (from the systematic review), based on their publication status, language etc. | Was a list of studies (included and excluded) provided? A list of included and excluded studies should be provided. | Were the characteristics of the included studies provided? In an aggregated form such as a table, data from the original studies should be provided on the participants, interventions and outcomes. The ranges of characteristics in all the studies analyzed e.g. age, race, sex, relevant socioeconomic data, disease status, duration, severity, or other diseases should be reported. | Was the scientific quality of the included studies assessed and documented? ‘A priori’ methods of assessment should be provided (e.g., for effectiveness studies if the author(s) chose to include only randomized, double-blind, placebo controlled studies, or allocation concealment as inclusion criteria); for other types of studies alternative items will be relevant.

Was the scientific quality of the included studies used appropriately in formulating conclusions? The results of the methodological rigor and scientific quality should be considered in the analysis and the conclusions of the review, and explicitly stated in formulating recommendations. | Were the methods used to combine the findings of studies appropriate? For the pooled results, a test should be done to ensure the studies were combinable, to assess their homogeneity (i.e. Chi-squared test for homogeneity, I²). If heterogeneity exists a random effects model should be used and/or the clinical appropriateness of combining should be taken into consideration (i.e. is it sensible to combine?). | Was the likelihood of publication bias assessed? An assessment of publication bias should include a combination of graphical aids (e.g., funnel plot, other available tests) and/or statistical tests (e.g., Egger regression test). | Was the conflict of interest stated? Potential sources of support should be clearly acknowledged in both the systematic review and the included studies.