# Empirical Evidence of Bias Search Strategies

All databases were searched from 1980 to September 24, 2012.

## Medline-OVID

January 19 2012

1. attrition bias*.tw.
2. selection bias*.tw.
3. detection bias*.tw.
4. performance bias*.tw.
5. reporting bias*.tw.
6. data bias*.tw.
7. mortality bias*.tw.
8. contamination bias*.tw.
9. differential treatment effect?.tw.
10. ecologic bias*.tw.
11. aggregate bias*.tw.
12. cross-level bias*.tw.
13. information bias*.tw.
14. publication bias*.tw.
15. suppression bias*.tw.
16. significance bias*.tw.
17. ((observer or intra-observer or intraobserver or inter-observer or interobserver) adj (bias* or variation*)).tw.
18. Co-intervention bias*.tw.
19. timing bias*.tw.
20. Compliance bias*.tw.
21. Withdrawal bias*.tw.
22. Proficiency bias*.tw.
23. performance bias*.tw.
24. or/1-23
25. exp in vitro study/
26. simulation/ or computer simulation/
27. simulation.tw.
28. 26 or 27
29. exp “bias (epidemiology)”/
30. 24 or 29
31. computer simulation/
32. simulation.tw.
33. 31 or 32
34. meta-analysis.pt,ti,ab,sh.
35. (meta anal$ or metaanal$).ti,ab,sh.
36. ((methodol$ or systematic$ or quantitativ$) adj3 (review$ or overview$ or survey$)).ti.
37. ((methodol$ or systematic$ or quantitativ$) adj3 (review$ or overview$ or survey$)).ab.
38. ((pool$ or combined or combining) adj (data or trials or studies or results)).ti,ab.
39. (medline or embase or cochrane or pubmed or pub med).ti,ab.
40. or/37-39
41. review.pt,sh.
42. 40 and 41
43. or/34-36
44. 42 or 43
45. exp DNA/
46. exp Genetics/
47. (genom* or genetic).ti.
48. or/45-47
49. “Quality Control”/
50. *“Meta-Analysis as Topic”/
51. 49 and 50
52. *“Randomized Controlled Trials as Topic”/
53. 49 and 52
54. 51 or 53
55. 30 not (25 or 48)
56. limit 55 to meta analysis
57. 33 and 55
58. 44 and 55
59. 56 or 57 or 58
60. limit 59 to english language
61. animals/
62. 60 not 61
63. limit 62 to (comment or editorial or in vitro or letter or video-audio media or webcasts)
64. 62 not 63
65. 54 or 59
66. limit 65 to english language
67. animals/
68. 66 not 67
69. limit 68 to (comment or editorial or in vitro or letter or video-audio media or webcasts)
70. 68 not 69

## Embase-OVID

January 19 2012

1. attrition bias*.tw.
2. selection bias*.tw.
3. detection bias*.tw.
4. performance bias*.tw.
5. reporting bias*.tw.
6. data bias*.tw.
7. mortality bias*.tw.
8. contamination bias*.tw.
9. differential treatment effect?.tw.
10. ecologic bias*.tw.
11. aggregate bias*.tw.
12. cross-level bias*.tw.
13. information bias*.tw.
14. publication bias*.tw.
15. suppression bias*.tw.
16. significance bias*.tw.
17. ((observer or intra-observer or intraobserver or inter-observer or interobserver) adj (bias* or variation*)).tw.
18. Co-intervention bias*.tw.
19. timing bias*.tw.
20. Compliance bias*.tw.
21. Withdrawal bias*.tw.
22. Proficiency bias*.tw.
23. performance bias*.tw.
24. or/1-23
25. *systematic error/ or external bias/ or internal bias/ or interview bias/ or nonresponse bias/ or observer bias/ or recall bias/
26. 24 or 25
27. exp in vitro study/
28. simulation/ or computer simulation/
29. simulation.tw.
30. 28 or 29
31. meta analysis/
32. meta-analysis.ti,ab.
33. (meta anal$ or metaanal$).ti,ab.
34. ((methodol$ or systematic$ or quantitativ$) adj3 (review$ or overview$ or survey$)).ti.
35. ((methodol$ or systematic$ or quantitativ$) adj3 (review$ or overview$ or survey$)).ab.
36. ((pool$ or combined or combining) adj (data or trials or studies or results)).ti,ab.
37. (medline or embase or cochrane or pubmed or pub med).ti,ab.
38. or/35-37
39. review.pt,sh.
40. 38 and 39
41. or/31-34
42. 40 or 41
43. exp *DNA/
44. exp genetics/
45. polymorphism.ti.
46. (laboratory or animal).ti.
47. or/43-46
48. “quality control”/
49. “meta analysis”/
50. 48 and 49
51. “statistical analysis”/
52. 50 and 51
53. 30 or 42
54. 27 or 47
55. 26 not 54
56. 53 and 55
57. 52 or 56
58. limit 55 to (meta analysis or “systematic review”)
59. 57 or 58
60. limit 59 to english language
61. animals/
62. 60 not 61
63. limit 62 to (book or book series or conference abstract or editorial or letter or note)
64. 62 not 63

## Cochrane-Wiley

January 19, 2012

All reviews by Cochrane Methods Group