# Results

The systematic search initially identified 24,984 potential articles; 5,857 were removed from this initial list because they were duplicates, leaving 19,127 titles to be reviewed (Figure 1). At the title-screening level, 15,685 titles were excluded, leaving 3,442 abstracts for review. At the abstract-screening level, 2,756 abstracts were removed, leaving 686 articles to be screened for eligibility for the questions addressed in this review. At the article-review level, 43 articles met the eligibility criteria (see Figure 1). The studies used a variety of study designs and were conducted in many countries (see Table 1). The country where the greatest number of studies was performed is the United Kingdom. Only five of the studies were performed in the United States, too few to support a separate analysis of U.S.-focused studies for each of our Key Questions (KQs). We decided to combine the information across countries, still accounting for specific situations, while formulating our conclusions.

Figure 1 Results of the literature search

^*^ Number of excluded articles sum is greater than because articles could be excluded for more than one reason

CINAHL = Cumulative Index to Nursing and Allied Health Literature

Figure 1 graphically details the number of unique articles identified by the searches used (19,127), the number excluded at title review (15,685), the number excluded at abstract review (2,756), and the number excluded through full article screening (643), leaving 43 articles eligible for discussion in this review.

Table 1 Types of studies assessing the impact of economic evidence on policymakers in health care

Country | N | Study Design | Reference
Argentina | 1 | Survey | Rubinstein, 2007^42^
Australia | 5 | Document review | Harris, 2008^43^ O'Malley, 2006^44^ George, 2001^45^
Australia | 5 | Qualitative case study | O'Malley, 2006^44^ George, 2001^45^ Weekes, 1996^46^ Ross, 1995^47^
Australia | 5 | Surveys and focus groups | Weekes, 1996^46^
Australia | 5 | Structured interviews | Ross, 1995^47^
Canada | 5 | Qualitative case study | Singer, 2000^48^ Martin, 2001^49^ PausJenssen, 2003^50^ Anis, 1998^51^
Canada | 5 | Documents review | Martin, 2001^49^ Anis, 1998^51^ Rocchi, 2008^52^
Canada | 5 | Focus group | Rocchi, 2008^52^
Canada | 5 | Interviews | Martin, 2001^49^
Germany | 1 | Qualitative case study, surveys, focus groups, directed interviews | Hoffmann, 2000^53^
Ghana | 1 | Discrete choice experiment | Jehu-Appiah, 2008^54^
Hungary | 1 | Statistical analysis | Grof, 2007^55^
Italy | 1 | Surveys | Fattore, 2006^56^
Nepal | 1 | Discrete choice experiment | Baltussen, 2007^57^
the Netherlands | 2 | Structured interviews | Zwart-van Rijkom, 2000^36^
the Netherlands | 2 | Qualitative case study | IJzerman, 2003^58^
the Netherlands | 2 | Surveys | Zwart-van Rijkom, 2000^36^ IJzerman, 2003^58^
the Netherlands | 2 | Semi-structured interviews | IJzerman, 2003^58^
Norway | 1 | Qualitative case study and structured interviews | Pedersen, 2008^59^
Sweden | 3 | Qualitative case study | Jansson 2007^60^ Anel, 2005^61^
Sweden | 3 | Surveys | Anel, 2005^61^ Jansson, 2007^60^
Sweden | 3 | Document reviews | Anel, 2005^61^
Thailand | 1 | Structured interviews | Teerawattananon, 2008^62^

## Findings

### KQ 1 Do economic data or analyses as reported in economic evaluation studies, including those as part of health technology assessments, comparative effectiveness research, or technology appraisals, impact policy decisions in health care?

In 30 of the 43 studies, the reviewers found evidence that use of economic evidence had a “substantial” impact on health care policymaking, either in general health policy or in specific policy topics such as individual reimbursement decisions or in relation to specific interventions or specific drugs used in particular diseases or conditions (see Table 2). The nature of this evidence varied by study design and varied from actual observations during decisionmaking in formal decisionmaking bodies, to recordings in formal documents such as economic dossiers, to verbal reports by responding decisionmakers, to answers to surveys. In 11 studies, the reviewers found evidence that use of economic evidence had only a “limited” impact on decisionmaking in health policy settings. In two studies, economic evidence had no impact on health care decisionmaking.

Table 2 Details of studies addressing the impact of economic evidence on policymakers in health care

Author, Year | Affiliation | Decisionmaking Body/Societal Actors | Policy Level | General or Disease Specific | Type of Decisionmaking Targeted | Type of Decisionmaking Criteria | Impact of Economic Evidence on Decisionmaking
Anell, 2005^61^ | Swedish Institute for Health Economics, Sweden | National policymakers | National, Local | General pharmaceuticals | Reimbursement decision | Cost-effectiveness/efficiency; Also focus on marginal utility principle; Budget impact; Equity: Principle of human dignity; Size of target population | Substantial
Anis, 1998^51^ | Department of Health Care and Epidemiology, University of British Columbia, Centre for Health Evaluation and Outcome Sciences, St Paul's Hospital, Vancouver, British Columbia, Canada | Subnational/regional policymakers | State, Provincial | General pharmaceuticals | Reimbursement decision | Cost-effectiveness/efficiency; Budget impact; Coverage, Cost-Minimization; Cost comparison/cost-consequence | Substantial
Baltussen, 2007^57^ | Department of Public Health, Radboud University Medical Center Nijmegen, the Netherlands | National program managers in Nepal | National | Lung health programs involving pneumonia, TB, COPD, and asthma; HIV/AIDS; Maternal and child health | Reimbursement decision | Cost-effectiveness/efficiency; Equity: Poverty reduction; Individual health benefits and number of potential beneficiaries; Age of target group; Stage of disease; Clinical effectiveness | Substantial
Bloom, 2004^37^ | Departments of Medicine and Health Care Systems and the Leonard Davis Institute of Health Economics, University of Pennsylvania, Philadelphia, U.S.A. | Policymakers, Technical experts, Public and Private payers | National | General surgical, and pharmaceutical interventions | Reimbursement decision; General policy and attitude on health; General policy or attitude on health financing; Research resource allocation | Benefits; Benefit/cost ratios; Timeliness | Substantial
Bryan, 2007^63^ | Health Economics Facility, University of Birmingham, U.K., and Center for Health Policy, Stanford University, U.S.A. | National health board | National | General health technology appraisals | Reimbursement decision | Cost-effectiveness/efficiency; Equity | Substantial
Chen, 2007^64^ | School of Pharmacy and Pharmaceutical Sciences, University of Manchester, U.K. and Ministry of Education, Taiwan | Local medical management committees | Local | General managed entry of new drugs, with focus on cost-effectiveness of parecoxib versus ketorolac. | General policy and attitude on health | Cost-effectiveness/efficiency; Budget impact | Limited
Dakin, 2006^65^ | Abacus International, U.K. | National health board | National | General | Reimbursement decision, Package decisions in general | Cost: Net Costs; Cost-effectiveness/efficiency; Burden of Disease; Uncertainty Surrounding ICER | Substantial
DiMasi, 2001^66^ | Director of Economic Analysis, Tufts Center for the Study of Drug Development, Tufts University, Boston, Massachusetts, U.S.A. | Pharmaceutical research and development departments | Internal/professional | General pharmaceutical research and development | Reimbursement decision; Research resource allocation | Cost: Cost-containment policy; Budget impact: Total % of budget allocated to pharmacoeconomics | Substantial
Duthie, 1999^67^ | Global Health Outcomes, Glaxo Wellcome Research and Development, Greenford Road, Greenford, Middlesex, U.K. | General practitioners, Purchasers | Professional/practice | General practice | Reimbursement decision; General policy and attitude on health; Purchasing, | Cost: Cost-effectiveness/efficiency; Budget impact: Horizon Scanning | Substantial
Eddama, 2008^68^ | National Perinatal Epidemiology Unit, University of Oxford, Department of Social Medicine, University of Bristol, U.K. | Policymakers and key public | Local | General | General policy and attitude on health | Cost: Cost-effectiveness/efficiency; Equity | None
Fattore, 2006^56^ | CERGAS-SDA, Bocconi University, Milan, Italy | Health care professionals | National, Local | Surgical intervention; Prevention services; Drugs; Diagnostic service; Rehabilitation | General policy and attitude on health | Cost-effectiveness/efficiency; Equity: Social demographics of participants; Perceptions of use of economic evaluations among health care professionals; Extent of use of economic evaluations of health care organizations for clinical and managerial decisionmaking; Participants perceived knowledge of economic evaluation. | Substantial
George, 2001^45^ | Centre for Policy and Practice, University of London School of Pharmacy, London, U.K. | National health board | National, The Commonwealth Government of Australia, Pharmaceutical Benefits Schedule | General pharmaceuticals | Reimbursement decision | Cost: Cost/QALY, Incremental cost-effectiveness ratio | Substantial
Gold, 2007^38^ | Department of Community Health and Social Medicine, The Sophie Davis School of Biomedical Education, New York, U.S.A. | General public, Randomly selected members of New York jury pool | National, Medicare | Primary care and acute care, including Treatment for erectile dysfunction; Physician counseling for smoking; Total hip replacement; Outreach for influenza and pneumonia vaccinations; Treatment of major depression; Gastric bypass surgery; Treatment for osteoporosis; Screening for colon cancer; Implantable cardioverter defibrillator; Lung-volume reduction surgery; Tight control of diabetes; Treating elevated cholesterol; Resuscitation after in-hospital cardiac arrest; Left ventricular assist device | Reimbursement decision; Package decisions in general; General policy and attitude on health; General policy on health care | Stage of disease: disease severity; Rule of rescue; Tradeoffs between quality and quantity of life; “Fair-innings” | Substantial
Grof, 2007^55^ | StratMed Kft., Pecs, Hungary | Policymakers and clinicians | National | Oncology | Package decisions in general; General policy and attitude on health; General policy on health care; Research resource allocation | Cost-effectiveness/efficiency; Equity: Distributive justice, Evidence-based medicine; Constitutional and human rights; Lay opinion | Substantial
Harris, 2008^43^ | Monash University, Victoria, Australia | National health board | National | Not specified | Reimbursement decision | Cost: Cost to government; Cost-effectiveness/efficiency: Economic model validity, Incremental cost per QALY, uncertainty of cost per QALY; Stage of disease; Level of Evidence; Quality of studies, Previous consideration by PBAC; Modeled cost; Modeled outcome | Substantial
Hoffmann, 2000^53^ | Universitaet Hannover, Institut fuer Versicherungsbetriebslehr, Hannover, Germany | National health board and national policymakers | National, State, Local, Professional/Practice | General decisions in clinical practice; pharmacy, and hiring | General policy and attitude on health; General policy or attitude on health financing | Primarily cost benefit analysis | Limited
Hoffmann, 2002^69^ | Centre for Health Economics, University of York, United Kingdom | Local level policymakers | National, Local | General | General policy and attitude on health | Cost: Cost-effectiveness/efficiency | Limited
IJzerman, 2003^58^ | Roessingh Research and Development, Enschede, the Netherlands | Local level | National and local | Rehabilitation medicine; Primary care | Reimbursement decision; General policy or attitude on health financing | Budget impact; Stage of disease; Quality of life | Substantial
Jansson, 2006^70^ | The Swedish Institute for Health Economics | National health board and sub-national policymakers | Local | General drug prescriptions | Reimbursement decision | Cost-effectiveness/efficiency; Budget impact; Cost minimization | Limited
Jansson, 2007^60^ | The Swedish Institute for Health Economics, Sweden | National health board | National, centralized review process to assist in making drug coverage decisions | General pharmaceuticals | Reimbursement decision; Subsidies | Cost-effectiveness/efficiency; Principle of human dignity; Principle of need and solidarity | Substantial
Jehu-Appiah, 2008^54^ | Policy Planning Monitoring and Evaluation Division, Ghana Health Service, Accra, Ghana | Informal national group or institution | National, Ghana | General primary care and acute care, including vaccines, childhood diseases, communicable diseases, reproductive health, and injuries | Package decisions in general; General policy and attitude on health; General policy on health care | Cost: Cost-effectiveness/efficiency; Age: children, women of reproductive age, older people; Stage of disease: Severity of disease; Other: Number of potential beneficiaries; Poverty reduction | Substantial
Martin, 2001^49^ | Departments of Health Policy, Management and Evaluation and Public Health Sciences and the Joint Centre for Bioethics, University of Toronto, Ontario, Canada | Regional authority | State, Provincial | Cancer | General policy or attitude on health financing | Equity; Benefit | Limited
Milewa, 2006^71^ | Brunel University, U.K. | Patient/family/consumer group; Advocacy research group; Research specialists; Health economists | National | General, including multiple sclerosis, growth hormone use, Non-Hodgkin's lymphoma, menstrual bleeding, rheumatoid arthritis, primary care; Public health | Package decisions in general; General policy on health care | Cost: Cost-effectiveness/efficiency; Advocacy; Hidden costs; Credibility | Substantial
O'Malley, 2006^44^ | Medical Intelligence, 13 Cudgee Street, Turramurra, Australia | Federal and national policymakers | Federal | General medical procedures and new technologies | Reimbursement decision | Cost-effectiveness/efficiency, Clinical effectiveness; Safety | Limited
PausJenssen, 2003^50^ | Department of Medicine, University of Saskatchewan, Saskatoon, Saskatchewan, Canada | Regional authority | State, Provincial | General formulary | Reimbursement decision | Cost: Cost-effectiveness/efficiency; Budget impact; Unit cost; Cost comparison | Substantial
Pedersen, 2008^59^ | Department of General Practice and Community Medicine, Section for Medical Ethics, University of Oslo, Oslo, Norway | Health care professionals | Clinical | End of life care | General policy on health care; Resource allocation | Moral/Ethical; Medical/Scientific | None
Prosser, 2005^72^ | The Infirmary, Liverpool, U.K. | Professionals; Pharmacists | National, Local | General primary care and public health | Package decisions in general; General policy and attitude on health; General policy on health care; General policy or attitude on health financing | Cost: Cost-effectiveness/efficiency; Equity; Ethnicity; Stage of disease | Substantial
Rocchi, 2008^52^ | Axia Research, Hamilton, Ontario, Canada | Health economics and health policy specialists | Federal, National | Oncology | Reimbursement decision | Cost: Cost-effectiveness/efficiency; Budget impact: Affordability, appropriate use; Equity; Preferred outcomes; Extent of benefit; Data limitations | Substantial
Ross, 1995^47^ | Centre for Health Economics Research and Evaluation, Department of Community Medicine, Westmead Hospital, Westmead, Australia | National and regional policymakers | Federal and regional health authorities | General pricing of new drugs; decisions on breast cancer screening and cervical cancer screening; low osmolar contrast media radiological examinations; optimal sizes of cardiac surgery and renal transplant units; out-patient accident and emergency services decision on whether or not to install a CT scanner; capital works over $2 million | General policy and attitude on health; General policy or attitude on health financing | None | Limited
Rubinstein, 2007^42^ | Institute for Clinical Effectiveness and Health Policy, Buenos Aires, Argentina | Pharmaceutical manufacturer; Patient/family/consumer group | National | General primary care, acute care, and public health | Package decisions in general; General policy and attitude on health; General policy on health care; General policy or attitude on health financing | Cost: Cost-effectiveness/efficiency; Equity; Advocacy | Substantial
Schlander, 2007^73^ | Institute for Innovation and Valuation in Health, Eschborn, Germany | National health board | National | Disease specific: ADHD treatment with methylphenidate atomoxetine, and dexamphetamine. | Evaluation of performance and robustness of NICE technology appraisal processes | Transparency; Relevance; Appeals; Enforcement | Substantial
Singer, 2000^48^ | University of Toronto Joint Centre for Bioethics, Toronto, Ontario, Canada | Regional authority | State, Provincial | Cardiac conditions; Cancer | General policy or attitude on health financing | Cost: Cost-effectiveness/efficiency; Equity; Benefit; Evidence; Pattern of death | Limited
Tappenden, 2007^74^ | School of Health and Related Research, The University of Sheffield, Sheffield, U.K. | National health board | National | General health technologies | Package decisions in general | Cost-effectiveness/efficiency; Age; Baseline health-related quality of life; Availability of other therapies; Uncertainty | Substantial
Taylor-Robinson, 2008^75^ | Division of Public Health, University of Liverpool, Liverpool, U.K. | Patient/family/consumer group; Senior academics with direct experience in policymaking; Directors of finance, Director of a public health observatory | National, Local | General: Primary care and public health | General policy on health care | Cost: Cost-effectiveness/efficiency; Advocacy; Perceptions of models | Substantial
Teerawattananon, 2008^62^ | Health Intervention and Technology Assessment Program, Ministry of Public Health, Nonthaburi, Thailand | Policymakers | National | Gall bladder disease; chronic kidney disease | Package decisions in general; General policy and attitude on health; General policy on health care | Cost: Cost-effectiveness/efficiency; Budget impact; Equity; Stage of disease | Limited
Towse, 2002^76^ | Office of Health Economics, London, U.K. | National policymakers | National | General technology and pharmaceutical | Reimbursement decision | Cost-effectiveness/efficiency; Budget impact; Equity; Cost per QALY; Clinical effectiveness | Substantial
Wallace, 2002^39^ | NR | Health care professionals | General/clinical | General clinical, including acute care, chronic therapy, risk factor reduction, screening, and surgical therapy | Clinical guideline development | Cost: Cost-effectiveness/efficiency | Limited
Watkins, 2006^40^ | Pharmacy manager, Formulary development, at Premera Blue Cross and University of Washington, U.S.A. | State authority, Formulary review | State | Type II Diabetes | Reimbursement decision | Cost-effectiveness/efficiency; cost/per QALY; Projected treatment costs; Age; Ethnicity; Stage of disease; Gender | Substantial
Weekes, 1996^46^ | New South Wales Therapeutic Assessment Group Inc., Sydney, Australia | Regional authority | The Drug and Therapeutics Committee is the pivotal policymaker at institutional levels | Internal medicine; nursing; pharmacy | Drug expenditures | Cost-effectiveness/efficiency; Efficient management of resources and quality of therapeutics | Substantial
Williams, 2007^77^ | Health Economics Facility, Health Services Management Centre, School of Public Policy, University of Birmingham, Birmingham, U.K. | National health board | National | Clinical conditions, including colorectal cancer, breast cancer, bipolar disorder, menstrual bleeding, non-Hodgkin's lymphoma, chronic myeloid leukemia, angina, and myocardial infarction. | Reimbursement decision | Cost-effectiveness/efficiency | Substantial
Williams, 2008^78^ | University of Birmingham, U.K. | National health board | National, Local | General: Primary care, acute care, and public health | Package decisions in general; General policy and attitude on health; General policy on health care; General policy or attitude on health financing | Cost-effectiveness/efficiency; Budget impact; Equity; Advocacy | Substantial
Wilson, 2007^79^ | Health Economics Support Programme, Health Economics Group, School of Medicine, Health Policy & Practice, University of East Anglia, Norwich, U.K. | Local policymakers | National | General primary and acute care, including Introduction of a community-based echocardiography service in the diagnosis of chronic heart failure; Introduction of a ‘hospital at home’ service for managing acute exacerbations of COPD; Use of Drotrecogin-alpha for severe sepsis in intensive care patients; Introduction of an opportunistic screening program for trachoma; IVF; Implementation of case management to prevent emergency admissions | General policy and attitude on health | Cost-effectiveness/efficiency; Budget impact: Burden; Equity and fairness; Deliverability; Engagement; Acceptability | Substantial
Zwart-van Rijkom, 2000^36^ | Erasmus University, Institute for Medical Technology Assessment, Rotterdam, the Netherlands | Policymakers and experts/professionals | National | Obesity | Package decisions in general; General policy and attitude on health; General policy on health care | Cost-effectiveness/efficiency; Knowledge of cost-benefit analysis/cost-utility analysis; Safety; Politics | Limited

ADHD = attention deficit, hyperactivity disorder; COPD = chronic obstructive pulmonary disease; CT = computerized tomography; ICER = International Centre for Economic Research; IVF = in-vitro fertilization; NICE = National Institute for Clinical Excellence; NR = not reported; QALY = quality-adjusted life-years; TB= tuberculosis; U.K. = United Kingdom

### KQ 2a What is the evidence that U.S. policymaking is differentially affected by the inclusion of economic data and analysis in systematic reviews as compared with international counterparts?

It seemed inappropriate to make a one-to-one comparison between results in the United States and results in any other country because most reports from other countries included the formal use of economic evidence while those from the United States did not. As shown in Table 1, 15 studies were performed in the United Kingdom. Five studies were performed in each of three countries: Australia, Canada, and the United States. No other country had more than three studies. The study of the use of economic evidence in health policy is scarce in the United States in relation to the numbers of economic evaluations reported, population size, or size of the health care budget. The number of studies in each country seemed to reflect the formal arrangements to include economic evidence in formal decisionmaking. Countries such as the United Kingdom and Australia have formally incorporated economic evidence in the decisionmaking process for over a decade.

All but one of the studies concerned policymaking within the context of the health care system in a single nation or setting. Only two studies, one by Zwart-van Rijkom36 and one by Bloom, 2004^37^ covered multiple countries, with both researchers carrying out surveys in four high-income countries. The Zwart-van Rijkom study was funded through a European grant. Ten articles did not name any funding source, while the others were funded either by general health funding agencies or other public health agencies or were self-financed. The research in Nepal and Ghana was carried out with support from external donor agencies. The research in two articles was reported to be co-funded by a pharmaceutical organization and took place in a U.S. setting.

In a comparison of the international results with the five U.S.-based studies, one can see that the five U.S. studies were very heterogeneous in the policymakers, policy settings, and health organizations addressed. One study by Gold38 focused on the understanding of economic evidence by the general public. This was the only study focusing on use by the general public. Two U.S. studies were done from the perspective of a pharmaceutical company. A study by Wallace39 reported the limited use of economic evidence in medical and other health professional guidelines. Watkins40 examined the use of economic evidence from a diabetes model in a policy setting. The study by Bloom37 involved 104 policymakers and professionals from a self-selected, convenience sample in four countries, including the United States. It is unclear how many U.S.-based respondents were included and how this was done. The heterogeneous nature of the U.S. studies made it difficult to compare the results with those for other countries. All five studies did not relate to any specific health policy context in the United States that formally incorporated economic evidence in decisionmaking.

### KQ 2b What is the evidence that the impact on decisionmakers of including economic data in systematic reviews has changed over the past two decades within health care policymaking in the United States or in other countries?

The evidence was insufficient to support any strong conclusion about temporal trends in the impact of economic evaluations on health care decisionmaking, with very little evidence on changes related to the use of economic data in systematic reviews. Out of 43 studies, only four (9%) were published before the year 2000. Fourteen studies (33%) were published between 2000 and 2005, and 25 studies were published after 2005 (58%). Although the formal and institutionalized use of economic evidence has increased,41 the study of the policy impact of economic evidence has not been increasing at the same rate or may even be lagging behind. The number and nature of the studies was too limited and too patchy by level and types of care, to observe time trends in health policy relevance. For some high-income countries, time series on the number of economic dossiers do exist (e.g., Australia, the United Kingdom). The rate of submission of economic dossiers fluctuated over time and might depend upon the number of new drugs or other interventions that are ready for market entry.

### KQ 3a Which types of decisionmakers are likely to be influenced by the inclusion of economic data and analysis in systematic reviews?

The majority of the study populations (22 studies) consisted of organized national-level or sub-national policymakers that were members of formal committees involved in decisionmaking. The subjects were included in surveys, focus groups, interviews, observational research, or, indirectly via document analyses. The population groups varied from national and local formal health committee members, the general public, groups of policymakers with positions in various health agencies, staff of companies, and specific professional groups. Eight studies involved health professionals or the general public. Next in number were the study populations with individual policymakers that held a position in health agencies but were not selected because of membership in a decisionmaking body (7 studies). Some of the study samples included health professionals. Four studies involved local decisionmakers in a formal position (2 studies) or in an informal way. Two studies included staff members of pharmaceutical companies.

As the majority of the studies concluded that economic evidence does impact decisionmaking, it is difficult to distinguish particular groups of policymakers that may be more inclined to use this type of evidence. It might be significant that, among the few studies including local-level policymakers, there was the one study with a negative conclusion. According to the reporting researchers, this was inherent to the limited room for local decisionmaking and the lack of power to change central health decisions to adapt to the local context.

### KQ 3b What is the evidence regarding the impact of the inclusion of economic data in systematic review across the various types of decisions?

There was high variability in the types of decisions impacted by economic data. A total of 24 studies involved general decisionmaking in the health fields related to package and/or reimbursement discussions and decisions. Seven studies were limited to issues related to the supply of pharmaceuticals. Six studies were focused on a particular clinical domain such as oncology or stage of disease (acute, rehabilitation, or end-of-life) and usually involved health professionals. The remaining studies focused on public health (2 studies) or used a particular clinical case as an example (2 studies).

Twenty six studies focused on taking specific, identifiable reimbursement or health package decisions, while 15 studies had a wider focus on making choices in health care and in health policy in general. One study focused on the use of economic evidence in professional health guidelines, while in two cases the focus could not be established.

Distinguishing central or national-level policymaking from any other types of policymaking, the findings indicated that economic evidence was more likely to be used at the national level than at the local level. The majority of the studies (27 studies) dealt with central, national-level policymaking. Within this group, eight studies also included more local levels of policymaking. Five studies dealt with policymaking at the State level and five studies focused on decisionmaking in clinical practice in general; the latter studies were all in Canada. Three studies dealt with local decisionmaking only while three studies dealt with Federal policymaking only and they were conducted in either Australia or Canada.

### KQ 3c and KQ 3d What is the evidence on the impact of economic information on multiple assessments across diseases as compared with multiple assessments in a specific disease area? What is the evidence on the impact of economic data included in multiple or single technology assessments across multiple areas as compared with the assessments of single technologies in specific disease areas?

Although the majority of studies (28 of 43) examined the impact of economic evidence from general assessments across diseases or clinical areas, a sizeable percentage of the studies (15 of 43) focused on the impact of economic evidence from assessments in a specific disease area, and 9 of those focused on a single technology. The use and impact of economic evidence did not differ substantially between the general assessments and the disease-specific or technology-specific assessments. The findings therefore suggested that economic evidence can have an impact on health care decisionmaking regardless of whether the economic evaluation included multiple diseases or multiple technologies, or a single disease or single technology.

### KQ 4a What is the evidence of the impact of specific standardized economic methods (cost-effectiveness analysis, cost-utility analysis, or budget impact analysis) on decisionmakers?

Most (34 of 43) of the studies were performed exploring the use of cost-effectiveness information (see Table 2). This may be a consequence of being one of the search terms and an inclusion criterion. Yet, a large number of studies also mentioned other types of economic information as the object of study. These mainly concerned budget (13 studies) and cost (8 studies) information, but also specifically cost-utility analyses that incorporated quality-adjusted life-years (QALYs). In some studies, the lack of transparency of the QALY approach was mentioned as an obstacle in the use of economic evidence for health decisionmaking.

### KQ 4b What is the evidence that decisionmakers are applying economic criteria using summary measures for efficiency and equity?

Among the 34 studies that reported results of the impact of cost-effectiveness outcomes as a formal decisionmaking criterion to select health interventions, only two studies focused exclusively on the cost-effectiveness criterion. The remaining 32 studies indicated that at least one other economic decisionmaking criterion was important. Often these involved equity considerations, usually ill-defined (14 studies). Other frequently cited decisionmaking criteria included: clinical effectiveness (3 studies); budget impact (13 studies); ethical reasons (1 study); advocacy (4 studies) (see Table 2).

### KQ 5 What modifying factors have been important promoters and barriers for the use of economic data in health care decisionmaking?

Four modifying factors have played a key role in how economic data were used in health care decisionmaking: quality, transparency, clarity and communication. Table 3 lists the number of times that particular factors have been mentioned in the selected studies as particularly favorable or unfavorable in promoting the use of economic evidence in health policy decisions.

Table 3 Modulating factors: Promoters and obstacles in health policy and times mentioned

Factor | Mentioned as Promoter (Articles) | Mentioned as Barrier (Articles) | Times Not Mentioned at All as Promoter or Barrier
Quality/transparency of the economic studies leading to the assessment. | Jehu-Appiah, 2008^54^ Williams, 2007^77^ Watkins, 2006^40^ Bryan, 2007^63^ Jansson, 2007^60^ Rocchi, 2008^52^ Hoffmann, 2002^69^ | Watkins, 2006^40^ Bryan, 2007^63^ Hoffmann, 2002^69^ Williams, 2008^78^ Rubinstein, 2007^42^ Teerawattananon, 2008^62^ Taylor-Robinson, 1998^75^ Bloom, 2004^37^ Fattore, 2006^56^ Baltussen, 2007^57^ Schlander, 2007^73^ Singer, 2000^48^ O'Malley, 2006^44^ IJzerman, 2003^58^ Towse, 2002^76^ Hoffmann, 2002^69^ Anis, 1998^51^ Ross, 1995^47^ | 18
Quality/transparency of the decisionmaking process. | Watkins, 2006^40^ Rocchi, 2008^52^ Teerawattananon, 2008^62^ Fattore, 2006^56^ Baltussen, 2007^57^ Schlander, 2007^73^ Harris, 2008^43^ Gold, 2007^38^ Jansson, 2006^70^ Milewa, 2006^71^ | Jehu-Appiah, 2008^54^ Williams, 2007^77^ Bryan, 2007^63^ Rubinstein, 2007^42^ Schlander, 2007^73^ Towse, 2002^76^ Harris, 2008^43^ Milewa, 2006^71^ Eddama, 2008^68^ Chen, 2007^64^ Wilson, 2007^79^ Dakin, 2006^65^ Duthie, 1999^67^ | 20
Communication (including lack of knowledge) | Williams, 2007^77^ Rocchi, 2008^52^ Hoffmann, 2002^69^ Fattore, 2006^56^ Gold, 2007^38^ Jansson, 2006^70^ | Bryan, 2007^63^ Jansson, 2007^60^ Williams, 2008^78^ Rubinstein, 2007^42^ Teerawattananon, 2008^62^ Taylor-Robinson, 1998^75^ Bloom, 2004^37^ Fattore, 2006^56^ Hoffmann, 2002^69^ Ross, 1995^47^ Milewa, 2006^71^ Eddama, 2008^68^ Chen, 2007^64^ Prosser, 2005^72^ Zwart-van Rijkom, 2000^36^ PausJenssen, 2003^50^ DiMasi, 2001^66^ | 20
Trust/reputation of the group or agent. | Williams, 2008^78^ Harris, 2008^43^ | Jehu-Appiah, 2008^54^ Bloom, 2004^37^ Anis, 1998^51^ Ross, 1995^47^ | 37
Acceptance/Bias (for example, political will). | Williams, 2007^77^ Bryan, 2007^63^ Bloom, 2004^37^ Towse, 2002^76^ Hoffmann, 2002^69^ Anis, 1998^51^ Harris, 2008^43^ Jansson, 2006^70^ Duthie, 1999^67^ PausJenssen, 2003^50^ DiMasi, 2001^66^ Tappenden, 2007^74^ Weekes, 1996^46^ Anell, 2005^61^ George, 2001^45^ | Jehu-Appiah, 2008^54^ Jansson, 2007^60^ Teerawattananon, 2008^62^ Bloom, 2004^37^ O'Malley, 2006^44^ Jansson, 2006^70^ Milewa, 2006^71^ Eddama, 2008^68^ Chen, 2007^64^ Wilson, 2007^79^ Duthie, 1999^67^ Zwart-van Rijkom, 2000^36^ Anell, 2005^61^ George, 2001^45^ Pedersen, 2008^59^ Wallace, 2002^39^ | 12
Size of target group. | Rocchi, 2008^52^ Anell, 2005^61^ | Teerawattananon, 2008^62^ IJzerman, 2003^58^ Zwart-van Rijkom, 2000^36^ Tappenden, 2007^74^ Anell, 2005^61^ | 36
Formalized decisionmaking process. | Jehu-Appiah, 2008^54^ Towse, 2002^76^ PausJenssen, 2003^50^ Weekes, 1996^46^ Anell, 2005^61^ | Jansson, 2007^60^ Baltussen, 2007^57^ IJzerman, 2003^58^ Wilson, 2007^79^ Prosser, 2005^72^ Tappenden, 2007^74^ | 33
Lack of economic information | Dakin, 2006^65^ Weekes, 1996^46^ | Hoffmann, 2002^69^ Williams, 2008^78^ Taylor-Robinson, 1998^75^ Schlander, 2007^73^ IJzerman, 2003^58^ Ross, 1995^47^ Prosser, 2005^72^ Zwart-van Rijkom, 2000^36^ Wallace, 2002^39^ Martin, 2001^49^ | 31
Lack of relevance | | Williams, 2007^77^ Jansson, 2007^60^ Hoffmann, 2002^69^ Ross, 1995^47^ Eddama, 2008^68^ Chen, 2007^64^ Dakin, 2006^65^ Duthie, 1999^67^ Prosser, 2005^72^ PausJenssen, 2003^50^ Tappenden, 2007^74^ | 32

Most often mentioned, in about half of the studies, were the quality and transparency of the original economic studies that provided the economic evidence for the decisionmaking process. What is striking is that study quality and transparency were seen as important promoting factors (7 studies) in the case of a well-presented study and as strong obstacles in the case of a badly presented study (18 studies). The transparency and quality of the decisionmaking process itself was a related factor. The selected studies mentioned this as a key characteristic in the use or rejection of the evidence in about the same frequency (10 and 13 studies respectively). The third factor was the clarity of the economic information itself and the way it was communicated. Six studies reported good communication as an important promoting factor. Communication barriers were reported in 17 of the studies. The principle of acceptance of an economic approach (e.g., the political will or ethical acceptance to use economic information) was another important factor.

Two of the studies did not mention any modulating factors at all. This is the consequence of the retrospective review: these factors were actually not part of the research questions of the selected study and, likely, not part of the original research. There were other types of obstacles listed nine times; all were listed only once (see Table 3).

It is striking that there were many more obstacles listed than promoting factors, in spite of the fact that the majority of studies reported that use of economic evidence had an impact on health care decisionmaking. Barriers that were frequently mentioned were the absence of economic information, the lack of relevance, and, less frequently, the size of the patient population, the transaction cost, and the reputation of the involved research agency or decisionmaking agency.

## Quality of Individual Studies and Grading of the Body of Evidence

Given the varying quality and the lack of control studies, we qualify these studies as presenting a low level of evidence. The methods in each study varied and were often a combination of various methods (see Table 1). Mostly qualitative research was combined with one or two other research methods (19 studies in total). The latter always included semi-structured interviews. Five studies used postal surveys only to collect information, while seven other studies combined one or multiple surveys with another method. Another four studies used discrete choice experiments to elicit opinions on economic evidence from policymakers at varying levels. Three studies analyzed documents with or without a contribution from focus group research. Two studies applied statistical methods to a qualitative evaluation of the decisionmaking process. Two studies used four different methods (survey, focus groups, document analyses, and structured interviews) to collect primary data.

Table 4 summarizes the quality of the studies. One can observe a huge range in the assessments of the observational studies (Table 4a) and the surveys (Table 4b). Only 11 out of the 37 observational studies (30%) received positive ratings for more than three items on the checklist. The quality ratings among the surveys had a less skewed distribution. It was difficult to draw conclusions from these studies because of how few there were.

Table 4 Summary of the quality of studies

Table 4a Quality ratings for the selected observational studies

Author, Year | Has the Author Rendered Transparent the Process by Which Data Have Been Collected, Analyzed, and Presented? | Did the Study Describe the Setting/Population From Which the Study Sample Was Drawn? | Were the Inclusion or Exclusion Criteria Described? | Does the Study Describe the Key Characteristics of Study Participants at Enrollment/Baseline? | Was the Type of Economic Evidence Described? | Do the Authors Report at Least One Objective Outcome From the Use of Economic Evidence? | Number of Items With Affirmative Ratings
Prosser, 2005^72^ | 1 | 1 | 1 | 1 | 1 | 1 | 6
Urdahl, 2006^80^ | 1 | 1 | 1 | 1 | 1 | 1 | 6
Taylor-Robinson, 1998^75^ | 1 | 1 | 1 | 1 | 1 | 1 | 6
Harris, 2008^43^ | 1 | 1 | 1 | 1 | 1 | 1 | 6
Teerawattananon, 2008^62^ | 1 | 1 | 0 | 1 | 1 | 1 | 5
Chen, 2007^64^ | 1 | 1 | 0 | 1 | 1 | 1 | 5
Watkins, 2006^40^ | 1 | 1 | 0 | 1 | 1 | 1 | 5
Williams, 2008^78^ | 1 | 1 | 0 | 0 | 1 | 1 | 4
Eddama, 2008^68^ | 1 | 1 | 0 | 1 | 1 | 0 | 4
Williams, 2007^77^ | 1 | 1 | 0 | 1 | 0 | 1 | 4
Rocchi, 2008^52^ | 0 | 1 | 1 | 1 | 1 | 0 | 4
Vuorenkoski, 2008^81^ | 1 | 0 | 0 | 0 | 1 | 1 | 3
Pedersen, 2008^59^ | 1 | 1 | 0 | 1 | 0 | 0 | 3
Towse, 2002^76^ | 1 | 1 | 0 | 0 | 1 | 0 | 3
Wallace, 2002^39^ | 1 | 0 | 0 | 0 | 1 | 1 | 3
Rubinstein, 2007^42^ | 1 | 0 | 0 | 0 | 1 | 0 | 2
Jansson, 2007^60^ | 1 | 1 | 0 | 0 | 0 | 0 | 2
O'Malley, 2006^44^ | 1 | 1 | 0 | 0 | 0 | 0 | 2
Bryan, 2007^63^ | 1 | 0 | 0 | 0 | 1 | 0 | 2
IJzerman, 2003^58^ | 1 | 0 | 0 | 0 | 0 | 1 | 2
Baltussen, 2007^57^ | 1 | 0 | 0 | 0 | 0 | 0 | 1
Wilson, 2007^79^ | 1 | 0 | 0 | 0 | 0 | 0 | 1
Schlander, 2007^73^ | 1 | 0 | 0 | 0 | 0 | 0 | 1
Milewa, 2006^71^ | 1 | 0 | 0 | 0 | 0 | 0 | 1
Weekes, 1996^46^ | 1 | 0 | 0 | 0 | 0 | 0 | 1
Singer, 2000^48^ | 1 | 0 | 0 | 0 | 0 | 0 | 1
Martin, 2001^49^ | 1 | 0 | 0 | 0 | 0 | 0 | 1
PausJenssen, 2003^50^ | 1 | 0 | 0 | 0 | 0 | 0 | 1
Anell, 2005^61^ | 0 | 0 | 0 | 0 | 0 | 0 | 0
Wallace, 2002^39^ | 1 | 1 | 0 | 0 | 0 | 0 | 2
George, 2001^45^ | 1 | 0 | 0 | 0 | 1 | 0 | 2
Hoffmann, 2000^53^ | 1 | 0 | 0 | 0 | 0 | 0 | 1
Duthie, 1999^67^ | 1 | 0 | 0 | 0 | 0 | 0 | 1
Anis, 1998^51^ | 1 | 0 | 0 | 0 | 1 | 0 | 2
Ross, 1995^47^ | 1 | 0 | 0 | 0 | 0 | 0 | 1

“1” = Yes, with detailed description

“0” = Yes, with some description, or no

Table 4b Quality ratings for the selected survey studies

Author, Year | Did the Study Describe the Setting or Population From Which the Study Sample Was Drawn? | Were the Inclusion/Exclusion Criteria Described? | Does the Study Describe Key Characteristics of Study Participants at Enrollment/Baseline? | Is There a Survey Completion Rate? | Is There Discussion of the Validity and Reliability of the Survey Instrument? | Number of Items With Affirmative Rating
Tappenden, 2007^74^ | 1 | 1 | 1 | 1 | 1 | 5
Bloom, 2004 37 | 1 | 1 | 1 | 1 | 0 | 4
Dakin, 2006^65^ | 1 | 1 | 1 | 0 | 1 | 4
Jansson, 2006^70^ | 1 | 0 | 1 | 1 | 1 | 4
Williams, 2008^78^ | 1 | 1 | 1 | 0 | 0 | 3
Gold, 2007^38^ | 1 | 1 | 1 | 0 | 0 | 3
Fattore, 2006^56^ | 1 | 1 | 0 | 1 | 0 | 3
Chen, 2007^64^ | 1 | 1 | 1 | 0 | 0 | 3
DiMasi, 2001^66^ | 1 | 0 | 0 | 1 | 0 | 2
Weekes, 1996^46^ | 1 | 0 | 0 | 0 | 0 | 1
Jehu-Appiah, 2008^54^ | 0 | 0 | 0 | 0 | 0 | 0
Zwart-van Rijkom, 2000^36^ | 0 | 0 | 0 | 0 | 0 | 0

“1” = Yes, with detailed description

“0” = Yes, with some description, or no

Table 5 provides a narrative overview of the grading of the body of evidence using the format as recommended in the Agency for Healthcare Research and Quality manual20 and using the study quality assessment as one of the criteria. The grading distinguishes three levels of policy use: specific reimbursement decisions, general reimbursement decisions, and general policymaking in all sorts of health decisionmaking. A qualitative summary statement is made in the last column, taking into account the body of real-life decisions studied, if any, and the reported preference of study subjects for using economic evidence.

Table 5 Strength of evidence on the impact of economic evidence in different types of health care decisions

Number of Studies and Subjects | Domains of Strength of Evidence | | | | Strength of Evidence Supporting an Impact
Number of Studies and Subjects | Design/Quality | Consistency | Directness | Precision | Strength of Evidence Supporting an Impact
Specific reimbursement decisions
9 studies; 10–30 policymakers | Observational studies of varying quality | Consistent | Direct | Precise | Low
General reimbursement decisions
19 studies; 10–104 policymakers | Surveys and observational studies of varying quality | Consistent | Direct | Imprecise | Low
General policy decisions
15 studies; 15–104 policymakers | Five studies with control options; Surveys and observational studies of varying quality | Consistent | Indirect | Imprecise | Intermediate

Consistency: agreement among studies; Directness: evidence of effect on real-life decisions; Precision: evidence of direct, one-to-one effect on real-life decisions; Risk of Bias: measure of individual study quality.

Strength of Evidence: High confidence means that the evidence reflects the true effect. Further research is very unlikely to change confidence in the estimate of effect. Intermediate confidence means that the evidence reflects the true effect. Further research may change confidence in the estimate of effect and may change the estimate. Low confidence means that the evidence reflects the true effect. Further research is likely to change the confidence in the estimate of effect and is likely to change the estimate. Insufficient evidence

Five observational studies used discrete choice experiments. This approach provided policymakers a comparison option in every discrete choice made. These are actually the only studies that incorporated some formal comparison option in the assessment of the importance of economic information. All the studies with experimental designs were done for policymaking at the general health policy level and not in relation to specific and general reimbursement situations. All five of these observational studies were done in non-U.S. settings. This finding, coupled with the modest number of U.S. studies, led to the conclusion that the available level of evidence for the United States is of lesser quality than the intermediate quality of studies from other countries. In the group of studies on actual reimbursement decisions, we only identified observational non-controlled studies on the use of economic evidence, considering single, multiple, even many (in Australia) reimbursement dossiers.