# References

1 Weinstein MC, Stason WB. Foundations of cost-effectiveness analysis for health and medical practices. N Engl J Med. 1977;296(13):716-21. [pmid: 402576].
2 Williams A. Cost-benefit analysis: bastard science? and/or insidious poison in the body politick?. Journal of Public Economics. 1972;1(2):199-225.
3 Williams I, Bryan S. Understanding the limited impact of economic evaluation in health care resource allocation: a conceptual framework. Health Policy. 2007;80(1):135-43. [pmid: 16621124].
4 Tunis SR. Economic analysis in healthcare decisions. Am J Manag Care. 2004;10(5):301-4. [pmid: 15152698].
5 Sculpher MJ, Drummond MF. Analysis Sans Frontieres - Can we ever make economic evaluations generalisable across jurisdictions?. Pharmacoeconomics. 2006;24(11):1087-99. [pmid: 17067194].
6 American College of Physicians. Information on cost-effectiveness: an essential product of a national comparative effectiveness program. Ann Intern Med. 2008;148(12):956-61. [pmid: 18483128].
7 Aspinall S, Good C, Glassman P, Valentino M. The evolving use of cost-effectiveness analysis in formulary management within the Department of Veterans Affairs. Med Care. 20-ii. 2005;43(7):II-26.
8 Berger ML, Teutsch S. Cost-effectiveness analysis: from science to application. Med Care. 2005;43(7 Suppl):49-53. [pmid: 16056009].
9 Cohen J, Stolk E, Niezen M. The increasingly complex fourth hurdle for pharmaceuticals. Pharmacoeconomics. 2007;25(9):727-34. [pmid: 17803332].
10 Colmenero F, Sullivan SD, Palmer JA, et al. Quality of clinical and economic evidence in dossier formulary submissions. Am J Managed Care. 2007;13(7):401-7.
11 Elixhauser A, Luce BR, Taylor WR, Reblando J. Health care CBA/CEA: an update on the growth and composition of the literature. Med Care. 1993;31(7 Suppl):JS1-11. JS18. 149. [pmid: 8326780].
12 Garber A. A menu without prices. Ann of Intern Med. 2008;148(12):964-6. [pmid: 18483127].
13 Gold MR, Sofaer S, Slegelberg T. Medicare and Cost-Effectiveness Analysis: Time to Ask the Taxpayers. Health Affairs. 2007;26(5):1399-406. [pmid: 17848451].
14 Luce BR. What Will It Take to Make Cost-Effectiveness Analysis Acceptable in the United States?. Med Care. 2005;43(7):44-8. [pmid: 16056008].
15 Neumann PJ, Palmer JA, Daniels N, et al. A strategic plan for integrating cost-effectiveness analysis into the US healthcare system. Am J Manag Care. 2008;14(4):185-8. [pmid: 18402510].
16 Neumann PJ, Greenberg D, Olchanski NV, Stone PW, Rosen AB. Growth and quality of the cost-utility literature, 1976-2001. Value Health. 2005;8(1):3-9. [pmid: 15841889].
17 Neumann PJ. Why don't Americans use cost-effectiveness analysis?. Am J Manag Care. 2004;10(5):308-12. [pmid: 15152700].
18 Sonnad SS, Greenberg D, Rosen AB, et al. Diffusion of published cost-utility analyses in the field of health policy and practice. Int J Technol Assess Health Care. 2005;21(3):399-402. [pmid: 16110721].
19 Frick K, Neissen L, Bridges J, Walker D, Wilson RF, Bass EB. Usefulness of Economic Evaluation Data in Systematic Reviews of Evidence, Methods Research Report. (Prepared by Johns Hopkins University Evidence-based Practice Center under contract No. 290-02-0018). AHRQ Publication No. 12-EHC114-EF. Rockville, MD. Agency for Healthcare Research and Quality. In process.
20 Agency for Healthcare Research and Quality. Methods Reference Guide for Effectiveness and Comparable Effectiveness Reviews, Version 1.0. Rockville, MD. 2007.
21 Evers S, Goossens M, de Vet H, et al. Criteria list for assessment of methodological quality of economic evaluations: Consensus on Health Economic Criteria. Int J Technol Assess Health Care. 2005;21(2):240-5. [pmid: 15921065].
22 Shemilt I, et al. Chapter 15: Incorporating economics evidence. Higgins JPT, editor. Cochrane Handbook for Systematic Reviews of Interventions. Wiley. 2008.
23 Hjelmgren J, Berggren F, Andersson F. Health economic guidelines--similarities, differences and some implications. Value Health. 2001;4(3):225-50. [pmid: 11705185].
24 Daniels N, Sabin JE. Accountability for reasonableness: an update. BMJ. 2008;337:a1850. [pmid: 18845595].
25 de Bont A, Zandwijken G, Stolk E, Niessen L. Prioritisation by physicians in the Netherlands--the growth hormone example in drug reimbursement decisions. Health Policy. 2007;80(3):369-77. [pmid: 16684580].
26 Kapiriri L, Norheim OF, Martin DK. Fairness and accountability for reasonableness. Do the views of priority setting decision makers differ across health systems and levels of decision making?. Soc Sci Med. 2009;68(4):766-73. [pmid: 19070414].
27 Barnett-Page E, Thomas J. Methods for the synthesis of qualitative research: a critical review. BMC Med Res Methodol. 2009;9:59. [pmid: 19671152].
28 Shea BJ, Grimshaw JM, Wells GA, et al. Development of AMSTAR: a measurement tool to assess the methodological quality of systematic reviews. BMC Med Res Methodol. 2007;7:10. [pmid: 17302989].
29 Lincoln TM, Rief W. How much do sample characteristics affect the effect size? An investigation of studies testing the treatment effects for social phobia. J Anxiety Disord. 2004;18(4):515-29. [pmid: 15149711].
30 Tobin GA, Begley CM. Methodological rigour within a qualitative framework. J Adv Nurs. 2004;48(4):388-96. [pmid: 15500533].
31 Horsburgh D. Evaluation of qualitative research. J Clin Nurs. 2003;12(2):307-12. [pmid: 12603565].
32 Normand SL, Sykora K, Li P, Mamdani M, Rochon PA, Anderson GM. Readers guide to critical appraisal of cohort studies: 3. Analytical strategies to reduce confounding. BMJ. 2005;330(7498):1021-3. [pmid: 15860831].
33 Mamdani M, Sykora K, Li P, et al. Reader's guide to critical appraisal of cohort studies: 2. Assessing potential for confounding. BMJ. 2005;330(7497):960-2. [pmid: 15845982].
34 Rochon PA, Gurwitz JH, Sykora K, et al. Reader's guide to critical appraisal of cohort studies: 1. Role and design. BMJ. 2005;330(7496):895-7. [pmid: 15831878].
35 Guyatt G, Oxman A, Kunz R, et al. Incorporating considerations of resources use into grading recommendations. BMJ. 2008;336(7654):1170-3. [pmid: 18497416].
36 Zwart-van Rijkom JE, Leufkens HG, Busschbach JJ, et al. Differences in Attitudes, Knowledge and Use of Economic Evaluations in Decision-Making in the Netherlands. The Dutch Results from the EUROMET Project. PharmacoEconomics. 2000;18(2):149-60. [pmid: 11067649].
37 Bloom BS. Use of Formal Benefit/Cost Evaluations in Health System Decision Making. Am J Managed Care. 2004;10(5):329-35.
38 Gold M, Franks P, Siegelberg T, Sofaer S. Does providing cost-effectiveness information change coverage priorities for citizens acting as social decision makers?. Health Policy. 2007;83(1):65-72. [pmid: 17204347].
39 Wallace JF, Weingarten SR, Chiou CF, et al. The limited incorporation of economic analyses in clinical practice guidelines. J Gen Intern Med. 2002;17(3):210-20. [pmid: 11929508].
40 Watkins JB, Minshall ME, Sullivan SD. Application of economic analyses in U.S. managed care formulary decisions: a private payer's experience. J Manag Care Pharm. 2006;12(9):726-35. [pmid: 17249905].
41 O'Donnell JC, Pham SV, Pashos CL, et al. Health technology assessment in evidence-based health care reimbursement decisions around the world: an overview. Value Health. Suppl. 2. 2009;12:S1-5. [pmid: 19523179].
42 Rubinstein A, Belizan M, Discacciati V. Are economic evaluations and health technology assessments increasingly demanded in times of rationing health services? The case of the argentine financial crisis. Int J Technol Assess Health Care. 2007;23(2):169-76. [pmid: 17493302].
43 Harris AH, Hill SR, Chin G, et al. The role of value for money in public insurance coverage decisions for drugs in Australia: a retrospective analysis 1994-2004. Med Decis Making. 2008;28(5):713-22. [pmid: 18378939].
44 O'Malley SP. The Australian experiment: the use of evidence based medicine for the reimbursement of surgical and diagnostic procedures (1998-2004). Aust New Zealand Health Policy. 2006;3:3. [pmid: 16684362].
45 George B, Harris A, Mitchell A. Cost-effectiveness analysis and the consistency of decision making: evidence from pharmaceutical reimbursement in Australia (1991 to 1996). Pharmacoeconomics. 2001;19(11):1103-9. [pmid: 11735677].
46 Weekes LM, Brooks C. Drug and Therapeutics Committees in Australia: Expected and actual performance. Br. J. Clin. Pharmacol. 1996;42(5):551-7. [pmid: 8951185].
47 Ross J. The use of economic evaluation in health care: Australian decision makers' perceptions. Health Policy. 1995;31(2):103-10. [pmid: 10141251].
48 Singer P, Martin D, Giacomini M, Purdy L. Priority setting for new technologies in medicine: qualitative case study. BMJ. 2000;321(7272):1316-9. [pmid: 11090513].
49 Martin D, Pater J, Singer P. Priority-setting decisions for new cancer drugs: a qualitative case study. Lancet. 2001;358(9294):1676-81. [pmid: 11728542].
50 PausJenssen AM, Singer PA, Detsky AS. Ontario's formulary committee: how recommendations are made. Pharmacoeconomics. 2003;21(4):285-94. [pmid: 12600223].
51 Anis AH, Rahman T, Schechter MT. Using pharmacoeconomic analysis to make drug insurance coverage decisions. Pharmacoeconomics. 1998;13(1 Pt 2):119-26. [pmid: 10176146].
52 Rocchi A, Menon D, Verma S, Miller E. The role of economic evidence in Canadian oncology reimbursement decision-making: to lambda and beyond. Value in Health. 2008;11(4):771-83. [pmid: 18179658].
53 Hoffmann C, Graf von der Schulenburg JM. The influence of economic evaluation studies on decision making. A European survey. The EUROMET group. Health Policy. 2000;52(3):179-92. [pmid: 10862993].
54 Jehu-Appiah C, Baltussen R, Acquah C, et al. Balancing equity and efficiency in health priorities in ghana: the use of multicriteria decision analysis. Value in Health. 2008;11(7):1081-7. [pmid: 19602214].
55 Grof A. Allocating resources for cancer control--resolving multicriteria decision-making using the analytic hierarchy process. A “daganatteher” csokkenteset szolgalo strategia valasztasanak modellezese. Analitikus hierarchikus eljaras alkalmazasa. Magy Onkol. 2007;51(3):197-208. [pmid: 17922059].
56 Fattore G, Torbica A. Economic evaluation in health care: the point of view of informed physicians. Value in Health. 2006;9(3):157-67. [pmid: 16689709].
57 Baltussen R, ten Asbroek AH, Koolman X, Shrestha N, Bhattarai P, Niessen LW. Priority setting using multiple criteria: should a lung health programme be implemented in Nepal?. Health Policy Plan. 2007;22(3):178-85. [pmid: 17412742].
58 IJzerman MJ, Reuzel RP, Severens HL. Pre-assessment to assess the match between cost-effectiveness results and decision makers' information needs: an illustration using two cases in rehabilitation medicine in The Netherlands. Int J Technol Assess Health Care. 2003;19(1):17-27. [pmid: 12701936].
59 Pedersen R, Nortvedt P, Nordhaug M, et al. In quest of justice? Clinical prioritization in healthcare for the aged. Journal of Medical Ethics. 2008;34(4):230-5. [pmid: 18375671].
60 Jansson S. Implementing accountability for reasonableness--the case of pharmaceutical reimbursement in sweden. Health Economics, Policy and Law. 2007;2(2):153-71.
61 Anell A, Persson U. Reimbursement and clinical guidance for pharmaceuticals in sweden: do health-economic evaluations support decision making?. European Journal of Health Economics. 2005;6(3):274-9. [pmid: 15968561].
62 Teerawattananon Y, Russell S. The greatest happiness of the greatest number? Policy actors' perspectives on the limits of economic evaluation as a tool for informing health care coverage decisions in Thailand. BMC Health Serv Res. 2008;8:197. [pmid: 18817579].
63 Bryan S, Williams I, McIver S. Seeing the NICE side of cost-effectiveness analysis: a qualitative investigation of the use of CEA in NICE technology appraisals. National Institute for Health & Clinical Excellence. Health Economics. 2007;16(2):179-93. [pmid: 16960851].
64 Chen LC, Ashcroft DM, Elliott RA. Do economic evaluations have a role in decision-making in Medicine Management Committees? A qualitative study. Pharm World Sci. 2007;29(6):661-70. [pmid: 17566869].
65 Dakin HA, Devlin NJ, Odeyemi IA. “Yes”, “No” or “Yes, but”? Multinomial modelling of NICE decision-making. Health Policy. 2006;77(3):352-67. [pmid: 16213624].
66 DiMasi JA, Caglarcan E, Wood-Armany M. Emerging role of pharmacoeconomics in the research and development decision-making process. Pharmacoeconomicsl. 2001;19(7):753-66.
67 Duthie T, Trueman P, Chancellor J, Diez L. Research into the use of health economics in decision making in the United Kingdom--Phase II. Is health economics ‘for good or evil’?. Health Policy. 1999;46(2):143-57. [pmid: 10346286].
68 Eddama O, Coast J. Use of economic evaluation in local health care decision-making in England: A qualitative investigation. Health Policy. 2008.
69 Hoffmann C, Stoykova BA, Nixon J, Glanville JM, Misso K, Drummond MF. Do health-care decision makers find economic evaluations useful? The findings of focus group research in UK health authorities. Value Health. 2002;5(2):71-8. [pmid: 11918822].
70 Jansson S, Anell A. The impact of decentralised drug-budgets in Sweden -- a survey of physicians' attitudes towards costs and cost-effectiveness. Health Policy. 2006;76(3):299-311. [pmid: 16046026].
71 Milewa T. Health technology adoption and the politics of governance in the UK. Soc Sci Med. 2006;63(12):3102-12. [pmid: 16982120].
72 Prosser H, Walley T. A qualitative study of GPs' and PCO stakeholders' views on the importance and influence of cost on prescribing. Soc Sci Med. 2005;60(6):1335-46. [pmid: 15626528].
73 Schlander M. NICE accountability for reasonableness: a qualitative study of its appraisal of treatments for attention-deficit/hyperactivity disorder (ADHD). Curr Med Res Opin. 2007;23(1):207-22. [pmid: 17261237].
74 Tappenden P, Brazier J, Ratcliffe J, Chilcott J. A stated preference binary choice experiment to explore NICE decision making. Pharmacoeconomics. 2007;25(8):685-93. [pmid: 17640110].
75 Taylor-Robinson D, Milton B, Lloyd-Williams F, et al. Policy-makers' attitudes to decision support models for coronary heart disease: a qualitative study. J Health Serv Res Policy. 2008;13(4):209-14. [pmid: 18806178].
76 Towse A, Pritchard C. National Institute for Clinical Excellence (NICE): Is economic appraisal working?. Pharmacoeconomics. Suppl 3. 2002;20:95-105. [pmid: 12457430].
77 Williams I, Bryan S, McIver S. How should cost-effectiveness analysis be used in health technology coverage decisions? Evidence from the National Institute for Health and Clinical Excellence approach. J. Health Serv Res Policy. 2007;12(2):73-9. [pmid: 17407655].
78 Williams I, McIver S, Moore D, Bryan S. The use of economic evaluations in NHS decision-making: a review and empirical investigation. Health Technol Assess. ix. x. 1. 2008;12(7):iii-175.
79 Wilson E, Sussex J, Macleod C, Fordham R. Prioritizing health technologies in a Primary Care Trust. J Health Serv Res Policy. 2007;12(2):80-5. [pmid: 17407656].
80 Urdahl H, Manca A, Sculpher MJ. Assessing generalisability in model-based economic evaluation studies - a structured review in osteoporosis. Pharmacoeconomics. 2006;24(12):1181-97. [pmid: 17129074].
81 Vuorenkoski L, Toiviainen H, Hemminki E. decision-making in priority setting for medicines - a review of empirical studies. Health Policy. 2008;86(1):1-9. [pmid: 17950484].
82 Guyatt G, Gutterman D, Baumann MH, et al. Grading strength of recommendations and quality of evidence in clinical guidelines: report from an American College of Chest Physicians Task Force. Chest. 2006;129(1):174-81. [pmid: 16424429].
83 Simoens S. Use of economic evaluation in decision making: evidence and recommendations for improvement. Drugs. 2010;70(15):1917-26. [pmid: 20883050].
84 Jirawattanapisal T, Kingkaew P, Lee T, Yang M. Evidence-based decision-making in Asia-Pacific with rapidly changing health-care systems: Thailand, South Korea, and Taiwan. Value in Health (Wiley-Blackwell). 2009;12:S4-11.
85 Tan SS, Rutten FFH, Hakkaart-van Roijen L. Incorporation of economic evidence in the Dutch guideline cardiovascular risk management'. J Eval Clin Pract. 2011;17:1094-101. [pmid: 21040249].
86 Chiou CF, Hay JW, Wallace JF, et al. Development and validation of a grading system for the quality of cost-effectiveness studies. Med Care. 2003;41(1):32-44. [pmid: 12544542].