# Discussion

The observed distribution of studies over time supports the observation that more attention has been paid to the use of economic evidence in policymaking during the past decade than before. Despite this and given the tens of thousands of economic studies and involvement of agencies in many countries, one can conclude this type of evaluation has been a neglected topic for the two decades that economic evidence has officially been introduced to policymakers. The United Kingdom had the most studies, although Australia, Canada, and Sweden also have an established tradition in the use of economic dossiers. Given the number of economic studies, it is rather surprising that there were so few U.S. or international studies on the use of economic information. We have found only one study in Latin America and only two in Asia.

However, it is not particularly surprising that these studies do not appear more frequently and are of lower quality in the U.S., given the limited structures and political will within the U.S. to deal with priority setting. Indeed, most health care policy settings in the world have hardly been evaluated for their use of economic evidence in conjunction with effectiveness and safety information.

We conclude that the use of economic evidence is recent and the proof of its actual use is patchy, limited, and of uneven quality. At best, the identified evidence fills only a very limited number of types of economic evidence distinguished within the overall framework that lists various policy levels, types of decisions (reimbursements, health packages, general health priorities), types of policymakers, professional and consumer groups, types of disease areas, and types of decision criteria.

The large majority of the identified studies do affirm that there has been use of economic evidence in health policy decisions. They report a limited list of barriers and promoting factors that influence use for decisionmaking. The majority of these are technical and transparency issues as is indicated by the formal application of the framework for reasonableness in the study by Schlander73 on the functioning of the United Kingdom–based National Institute for Clinical Excellence (NICE). Giving attention to barriers such as lack of transparency could lead to better use in health policy, at least in the areas that have been researched.

## Methodological Aspects

Our review is limited by the quality of the original studies and the overall paucity of research on the topic. Although we eliminated a large number of articles that did not report original data, we did include relevant studies using any quantitative or qualitative study design. This review is further limited to include only studies whose major focus, as identified in the title or abstract, is the impact of economic evidence in decisionmaking rather than a distal component.

Ideally, a systematic review of this kind seeks to provide an answer to the question: Is economic evidence influencing policymaking and what are the influential factors? An ideal way to do this would be using a randomized design. In all the selected studies there has been no comparison with decisionmaking without explicit economic evidence. It very well may be that economic arguments come up in any kind of decisionmaking context and are considered of importance or even guide the final decisions. The precise question then would be on the added value of evidence from formalized, systematic economic research.

The study findings and the review findings might be subject to various types of selection biases that may include both funding and publication processes. In addition to the quality of the studies and the design issues, there are, of course, various selection biases in reporting the use of economic evidence: selection biases while choosing the topics of study and the population of subjects; biases in the selection of the research groups; and, not least, publication bias, leading to a greater selection of positive studies. These biases may very well partly explain the overall positive conclusions of the studies.

## Generalizability and Transferability of Results—Limitations

A majority of articles concluded that economic arguments do play a role in decisionmaking, and only two articles reported a negative conclusion. Most of the articles based their findings on surveys among actors in the field or by studying existing policy practices.

Two other issues deserve attention. We found that the total body of evidence is of only intermediate strength. Only a few studies included comparison situations, in some way. In reality, we have not found attempts to compare health policy outcomes both with and without economic evidence (the highest level of evidence in the GRADE system).82

A second limitation is that most studies did not make a distinction between using economic arguments and using economic, research-based evidence. Here, one can only conclude that the added value of economic research, as compared to economic arguments, is based on its scientific quality.

These limitations indicate a need for additional original research on the usefulness and impact of economic evaluations. Such research could include surveys, focus group analyses, and case studies.

Despite these limitations, the body of literature reviewed favors the inclusion of economic evidence in policymaking in a variety of jurisdictions and specific policy areas. However, these findings are rather patchy evidence across the whole field when one considers the enormous number of possible areas and settings in health policymaking.

It is obvious that the effectiveness of economic evidence to influence policymaking will differ between countries, given the differences in cultural, economic, political, and infrastructural characteristics of the various health systems. These differences can already be observed in the variety of health care systems in which the scarce case studies in the various high-income countries took place.

## Strategies to Improve the Use of the Economic Evidence

One can make some conclusions based on the fact that there were four clear factors that promote or discourage health policy use of economic evidence. The review concludes that the use of economic evidence in real-life policymaking would be enhanced by improving the quality and transparency of the original economic studies, the quality and transparency of the decisionmaking process itself, and the clarity of the economic information itself and the way it is communicated. Communication has also been emphasized in other reviews of the use of economic evaluation in decisionmaking with one article suggesting the importance of researchers not ignoring the context of the decisions that will be made based on their results and taking the time to discuss how decisionmakers can use the economic evaluation results.83 Of course, the formalization of these processes in the various countries has been and will have to continue to be tailored to fit the existing national and local health policymaking processes and societal and organizational cultures. There are examples including Thailand, South Korea, and Taiwan, in which although there was not a formal study meeting our inclusion criteria, their systems for both generating and using cost-effectiveness data have been described and can be used as exemplars for other cases.84 While these three countries provide example of using cost-effectiveness information, it is also important to recognize that economic evaluation is confined only to cost-effectiveness but can also include budget impact which is of the most direct relevance to many decisionmakers including, in one example also not included in our review, in the Netherlands in cases related to cardiovascular risk management.85

We based our review approach on the Daniels and Sabin, 2008^24^ framework for accountability of reasonableness which says that better quality, accessibility, and transparency of the information promotes a fair and accepted process (see Box 1). In addition, use is promoted by fairness and transparency of the decisionmaking process in health policy itself. In the past decade, this framework has been used to evaluate policy processes in a number of settings. This turns out to be feasible both in high-income settings25,86 and in other settings.26

Increased transparency of economic evaluation and the decisionmaking process will have to be built on best standards for good practices, a common framework for the use of economic evidence for the possible actors involved,19 and more guidance on how to include this in the systematic review processes. Our findings indicate that any improvement to arrive at transparent economic evaluations and a transparent policy process would contribute to better use of economic studies.

## Conclusion/Discussion

We found relatively weak evidence on the use of economic evidence in the United States for policymaking, but intermediate strength of evidence in other high-income and some low-income countries. The literature supports the conclusion that the utility of economic evidence is influenced by technical issues, such as transparency and clarity, as well as by the transparency of the decisionmaking process.