# Excluded Articles

German recommendations for health care economic evaluation studies. Revised version of the Hannover consensus. Hannover Consensus Group. Med Klin (Munich). 2000;95(1):52-5. No original analysis; Other. [pmid: 10668346].
German recommendations for health economic evaluation. Revised edition of the Hannoverian consensus. Hannoverian Consensus Group. Dtsch Med Wochenschr. 1999;124(49):1503-6. Other. [pmid: 10629671].
Adeoye S, Bozic KJ. Influence of economic evaluations on public health policy. Curr Opin Orthop. 2007;18(1):28-32. No original analysis.
Al MJ, Feenstra T, Brouwer WBF. Decision makers' views on health care objectives and budget constraints: results from a pilot study. Health Policy. 2004;70(1):33-48. Does not apply to Economics, Does not apply to health or healthcare. [pmid: 15312708].
Alabbadi I, Crealey G, Scott M, et al. Impact of modified system of objectified judgement analysis (SOJA) methodology on prescribing costs of ACE inhibitors. Clin Drug Invest. 2006;26(9):485-494. Methods only.
Amaro H, Blake SM, Morrill AC, et al. HIV prevention community planning: challenges and opportunities for data-informed decision-making. AIDS Behav. 2005;9(2):S9-27. No cost effectiveness analysis. [pmid: 15933831].
Anderson J. Clinical practice guidelines: review of the recommendations for colorectal screening. Geriatrics. 2000;55(2):67-74. Does not apply to Economics, Focuses on single condition. [pmid: 10711308].
Anderson SE, Chen YK. Applying economic analysis to the decision-making process. Cost Qual Q J. 1997;3(4):9. No original analysis. [pmid: 10176232].
Anderson WL, Kenney GS, Rabiner DJ. Adoption of retrospective Medicare maximization billing practices by state Medicaid home care programs. J Health Polit Policy Law. 2003;28(5):859-881. Limited case study, No decision making, Other. [pmid: 14604215].
Anell A. Priority setting for pharmaceuticals: the use of health economic evidence by reimbursement and clinical guidance committees. Eur J Health Econ. 2004;5(1):28-35. Article of interest, Does not apply to Economics, Does not apply to health or healthcare. [pmid: 15452762].
Anis AH, Gagnon Y. Using economic evaluations to make formulary coverage decisions: so much for guidelines. Pharmacoeconomics. 2000;18(1):55-62. Not Aim 3 but applies to Aim 2. [pmid: 11010604].
Annemans L. Methodological issues in evaluating cost effectiveness of adjuvant aromatase inhibitors in early breast cancer: A need for improved modelling to aid decision making. Pharmacoeconomics. 2008;26(5):409-423. No original analysis. [pmid: 18429657].
Apostolakis GE, Pickett SE. Deliberation: Integrating analytical results into environmental decisions involving multiple stakeholders. Risk Anal. 1998;18(5):621-634. Does not apply to Economics, Does not apply to health or healthcare.
Appleby J, Devlin N, Parkin D. NICE's cost effectiveness threshold. BMJ. 2007;335(7616):358-359. No original analysis. [pmid: 17717337].
Arnaboldi M, Lapsley I. Activity based costing in healthcare: a UK case study. Research in Healthcare Financial Management. 2005;10(1):61-75. Costing study.
Arnold RJ. Cost-effectiveness analysis: should it be required for drug registration and beyond?. Drug Discov Today. 2007;12(21-22):960-5. No original analysis. [pmid: 17993415].
Arredondo A, Parada I. Trends on generation and reproduction of knowledge about economic evaluation and health. Rev Med Chil. 2001;129(8):925-34. No decision making, No original analysis, Other. [pmid: 11680968].
Arellano LE, Reza M, Blasco JA, et al. A content analysis of Health Technology Assessment programs in Latin America. Int J Technol Assess Health Care. 2009:570-6. Focuses on single condition with limited economic evaluation. [pmid: 19845988].
Asch DA, Hershey JC. Academic and clinic. Why some health policies don't make sense at the bedside. Ann Intern Med. 1995;122(11):846-850. Article of interest, No original analysis. [pmid: 7741370].
Aspinall SL, Good CB, Glassman PA, et al. The evolving use of cost-effectiveness analysis in formulary management within the Department of Veterans Affairs. Med Care. 20-ii. 2005;43(7):II-26. No original analysis.
Assael LA. What works? What does it cost? Comparative studies will drive decisions in health care reform. J Oral Maxillofac Surg. (02782391). 2010:1-2. Other. [pmid: 20006146].
Atkins D, DiGuiseppi CG. Broadening the evidence base for evidence-based guidelines: A research agenda based on the work of the U.S. preventive services task force. Am J Prev Med. 1998;14(4):335-344. Article of interest, No original analysis. [pmid: 9635080].
Aucott JN, Pelecanos E, Dombrowski R, et al. Implementation of local guidelines for cost-effective management of hypertension. A trial of the firm system. J Gen Intern Med. 1996;11(3):139-46. No cost effectiveness analysis. [pmid: 8667090].
Badia X, Rovira J, Segu JL, et al. Economic assessment of drugs in Spain. Pharmacoeconomics. 1994;5(2):123-129. No original analysis. [pmid: 10146905].
Bae EY. Guidelines for economic evaluation of pharmaceuticals in Korea. J Prev Med Pub Health. 2008;41(2):80-83. Other. [pmid: 18385547].
Baghbanian A, Hughes I, Khavarpour FA. Resource allocation and economic evaluation in Australia's healthcare system. Aust Health Rev. Aug. 2011;35(3):278-83. No application of EE to decision making. [pmid: 21871187].
Bailey HH, Kind P, Dan DV, et al. The role of economic evaluation in changing decision-maker behaviors: a case study from Trinidad and Tobago. Value Health. 2008;11(3):A308-A309. Does not apply to Economics, Limited case study.
Baladi JF, Menon D, Otten N. Use of economic evaluation guidelines: 2 years' experience in Canada. Health Econ. (GBR). 1998;7(3):221-227. Not Aim 3 but applies to Aim 2.
Barbieri M, Hawkins N, Sculpher M. Who does the numbers? The role of third-party technology assessment to inform health systems' decision-making about the funding of health technologies. Value Health. 2008. Does not apply to Economics, Methods only.
Baron J, Ubel PA. Revising a priority list based on cost-effectiveness: the role of the prominence effect and distorted utility judgments. Med Decis Making. 2001;21(4):278-87. No original analysis, Other. [pmid: 11475384].
Barton GR, Briggs AH, Fenwick EAL. Optimal cost-effectiveness decisions: the role of the cost-effectiveness acceptability curve (ceac), the cost-effectiveness acceptability frontier (ceaf), and the expected value of perfection information (evpi). Value Health. 2008;11(5):886-897. No decision making, Methods only. [pmid: 18489513].
Basu A, Bellis A. Implementing NICE guidelines: the difficulties. National Institute for Clinical Excellence. Clin Govern Int J. 2007;12(4):267-269. Does not apply to Economics.
Bate A, Mitton C. Application of economic principles in healthcare priority setting. Expert Rev. Pharmacoecon. Outcomes Res. 2006;6(3):275-284. Article of interest, Methods only, Other. [pmid: 20528521].
Batista MR, Gonzalez OE. Evaluation of surveillance in primary health care: a methodological proposal. Rev Cubana Med Trop. 2000;52(1):55-65. No original analysis, Other. [pmid: 11107895].
Beard K. Systems for evaluation of new drugs in the United Kingdom. Pharmacoepidemiol Drug Saf. 2001;10(5):439-43. No original analysis, Other. [pmid: 11802590].
Benson BL, Rasmussen DW. The context of drug policy: An economic interpretation. J. Drug Issues. 1998;28(3):681-699. No original analysis, Other.
Bentkover JD, Corey R. Effective utilization of pharmacoeconomics for decision makers. disease management and health outcomes. 2002;10(2):75-80. Methods only, No original analysis.
Berg M, Grinten TVD, et al. Technology assessment, priority setting, and appropriate care in Dutch health care. Int J Technol Assess Health Care. 2004;20(1):35-43. Does not apply to Economics, No original analysis. [pmid: 15176175].
Berger M, Honig P, Spatz I. Medicare and cost-effectiveness analysis. N Engl J Med. 2006;354(2):207-9. author reply 207-9. No original analysis. [pmid: 16411304].
Bernhardy JH. Strategies for successful technology assessment. Soc Sci Med. 2001;7(6):23-29. No decision making, No original analysis.
Best L, Stevens A, Colin-Jones D. Rapid and responsive health technology assessment: the development and evaluation process in the South and West region of England. Br J Clin Govern. 1997;2(2):51-56. No original analysis, Other.
Beutels P, Edmunds WJ, Antonanzas F, et al. Economic evaluation of vaccination programmes: a consensus statement focusing on viral hepatitis. Pharmacoeconomics. 2002;20(1):1-7. Methods only, No original analysis. [pmid: 11817988].
Beutels P, Scuffham PA, MacIntyre CR. Funding of drugs: do vaccines warrant a different approach?. Lancet Infect Dis. 2008;8(11):727-733. Methods only. [pmid: 18992409].
Birch S, Gafni A. Economists dream or nightmare? Maximizing health gains from available resources using the NICE Guidelines. Health Econ Policy Law. 2007;2(2):193-202. No original analysis. [pmid: 18634662].
Bloom BS, Bruno DJ, Maman DY, et al. Usefulness of US cost-of-illness studies in healthcare decision making. Pharmacoeconomics. 2001;19(2):207-213. Costing study, No cost effectiveness analysis, Other. [pmid: 11284384].
Bloor K, Maynard A, Freemantle N. Lessons from international experience in controlling pharmaceutical expenditure III: Regulating industry. BMJ. 1996;313(7048):33-35. Article of interest, No original analysis. [pmid: 8664771].
Blumstein JF. The Oregon experiment: the role of cost-benefit analysis in the allocation of Medicaid funds. Soc Sci Med. 1997;45(4):545-554. Article of interest, No original analysis. [pmid: 9226780].
Boersma C, Atthobari J, Gansevoort RT, et al. Pharmacoeconomics of angiotensin ii antagonists in type 2 diabetic patients with nephropathy - implications for decision making. Pharmacoeconomics. 2006;24(6):523-535. No decision making. [pmid: 16761901].
Borg P, Fogelholm M. Stakeholder appraisal of policy options for responding to obesity in Finland. Obes Rev. 2007;8(Suppl):247-52. Does not apply to Economics, No original analysis.
Bos Jasper M, Postma Maarten J. Using Pharmacoeconomics for policy making: is rational decision making enhanced by applying thresholds for cost-effectiveness?. Expert Rev Pharmacoecon Outcomes Res. 2004;4(3):247-250. No original analysis. [pmid: 19807306].
Boyle JM, McCartney E, O'Hare A, Forbes J. Direct versus indirect and individual versus group modes of language therapy for children with primary language impairment: principal outcomes from a randomized controlled trial and economic evaluation. Int J Lang Commun Disord. 2009:826-846. No decision making component. [pmid: 19107656].
Blacksher E. Health reform: what's prevention got to do with it?. Hastings Center Report. 2009. back page-. Other.
Bradley CA, Iskedjian M, Lanctot KL, et al. Quality assessment of economic evaluations in selected pharmacy, medical, and health economics journals. Ann Pharmacother. 1995;29(7-8):681-9. No original analysis. [pmid: 8520080].
Braithwaite RS, Roberts MS, Justice AC. Incorporating quality of evidence into decision analytic modeling. Ann Intern Med. 2007;146(2):133-141. Methods only, No decision making, Other. [pmid: 17227937].
Brauer CA, Neumann PJ, Rosen AB. Trends in cost effectiveness analyses in orthopaedic surgery. Clin Orthop Relat Res. 2007;457:42-8. No decision making, Other. [pmid: 17242614].
Brazier J, Deverill M, Green C. A review of the use of health status measures in economic evaluation. J Health Serv Res Policy. 1999;4(3):174-84. Does not apply to Economics, Methods only, Other. [pmid: 10538884].
Bruggenjurgen B. Aspects of health economic evaluations as a contribution to the priority-setting debate in Germany. Bundesgesundheitsblatt Gesundheitsforschung Gesundheitsschutz. 2010:890-5. Other. [pmid: 20853085].
Bujkiewicz S, Jones HE, Lai MC, et al. Development of a transparent interactive decision interrogator to facilitate the decision-making process in health care. Value Health. 2011:768-76. Other. [pmid: 21839417].
Busse R, Graf von, der Schulenburg JM, et al. Evaluation of cost effectiveness in primary health care. Z Arztl Fortbild Qualitatssich. 1997;91(5):447-55. No original analysis, Other. [pmid: 9377699].
Busse R, Orvain J, Velasco M, et al. Best practice in undertaking and reporting health technology assessments-Working Group 4 Report. Int J Technol Assess Health Care. 2002;18(2):361-422. Article of interest, Other. [pmid: 12053427].
Butcher L. The Oncology Times interview. United Healthcare's Lee Newcomer, MD: let's change incentives to reimburse oncologists for taking time to think about cost-effective treatments with same outcome as more expensive methods. Oncology Times. 2008;30(6):44-48. No original analysis.
Buxton MJ. Economic evaluation and decision making in the UK. Pharmacoeconomics. 2006;24(11):1133-42. Article of interest, No original analysis, Other. [pmid: 17067197].
Cairns J. Providing guidance to the NHS: the Scottish Medicines Consortium and the National Institute for Clinical Excellence compared. Health Policy. 2006;76(2):134-143. No original analysis, Other. [pmid: 15982779].
Calhoun BC, Hume RF. Out-sourcing medical care: what clinicians choose does matter. J Appl Res. 2002;2(1):63-68. Costing study, No cost effectiveness analysis.
Camerer Colin F, Kunreuther H. Decision processes for low probability events: policy implications. J Policy Anal Manage. 1989;8(4):565-592. Does not apply to health or healthcare, No cost effectiveness analysis, No original analysis.
Campbell RK. Strategies in the treatment of insulin resistance and type 2 diabetes mellitus. Am J Health Syst Pharm. 2002;59(23):S1-24. Does not apply to Economics, No cost effectiveness analysis, No original analysis, Other.
Campo K, De Staebel O, Gijsbrechts E, et al. Physicians' decision process for drug prescription and the impact of pharmaceutical marketing mix instruments. Health Mark Q. 2005;22(4):73-107. Does not apply to Economics, Limited case study, No cost effectiveness analysis. [pmid: 16597584].
Cantor JC. Health policy reform and the states. Adv Health Econ Health Serv Res. Greenwich, Conn. and London. JAI Press. 1995;(15):1-224. No original analysis, Other.
Carande-Kulis VG, Maciosek MV, Briss PA, et al. Methods for systematic reviews of economic evaluations for the Guide to Community Preventive Services. Task Force on Community Preventive Services. Am J Prev Med. 2000;18(1 Suppl):75-91. Article of interest, Methods only. [pmid: 10806980].
Caro JJ, Nord E, Siebert U, et al. The efficiency frontier approach to economic evaluation of health-care interventions. Health Econ. 2010:1117-27. Other. [pmid: 20575151].
Castiel D, Brechat PH, Benoit B, et al. Complete cost of surgery for postpartum haemorrhage. Gynecol Obstet Fertil. 2008;36(5):507-15. Costing study, Other. [pmid: 18472291].
Castillo-Laborde C. Economic evaluation in the health care decision making process: The case of England. Revista Medica De Chile. 2010:103-107. Also, this just looks like a comment--not science, Not in English.
United States Department of Health and Human Services, Public Health Service, Agency for Health Care Policy and Research. Cataract in adults: management of functional impairment. J Ophthalmic Nurs Technol. Jul- Aug. 1993;12(4):159-62. Does not apply to Economics, Limited case study. [pmid: 8301672].
Cazin JL, Gosselin P. Implementing a multiple-isolator unit for centralized preparation of cytotoxic drugs in a cancer center pharmacy. Pharm World Sci. 1999;21(4):177-183. Does not apply to Economics. [pmid: 10483606].
Chambers JD, Cohen JT, Neumann PJ, et al. Using cost-effectiveness information to allocate Medicare resources - How much more health for the money?. Value Health. 2011:A10-A11. Not EE and no decision making component.
Chambers JD, Neumann PJ, Buxton MJ. Does Medicare have an implicit cost-effectiveness threshold?. Med Decis Making. 2010:E14-E27. No EE in decision making. [pmid: 20551473].
Chang JC, Chen TH, Duffy SW, et al. Decision modelling of economic evaluation of intervention programme of breast cancer. J Eval Clin Pract. 2010:1282-1288. Other. [pmid: 20831661].
Chang L, Hung JH. The effects of the global budget system on cost containment and the quality of care: experience in Taiwan. Health Serv Manage Res. 2008;21(2):106-16. Does not apply to Economics, Does not apply to health or healthcare. [pmid: 18482934].
Charvet-Protat S. Medico-economic analysis of nosocomial infections. Presse Med. 2000;29(32):1782-7. No decision making, No original analysis, Other. [pmid: 11098279].
Cheng R, Cook K, Dowman S, et al. Health professionals: how do they assess new medicines?. Pharm World Sci. 2005;27(3):236-242. Clinician-level decision making only, No cost effectiveness analysis, Other. [pmid: 16096894].
Chiou CF, Hay JW, Wallace JF, et al. Development and validation of a grading system for the quality of cost-effectiveness studies. Med Care. 2003;41(1):32-44. Not Aim 3 but applies to Aim 2. [pmid: 12544542].
Cho E, Kang M. Public accountability and social judgment in the reimbursement decision for oncology medications in Korea. Value Health. 2011:A465. Meeting no paper?.
Chu H, Liu S, Romeis JC. Changes in prescribing behaviors after implementing drug reimbursement rate reduction policy in Taiwan: implications for the Medicare system. J Health Care Finance. 2008;34(3):45-54. Costing study. [pmid: 18468378].
Clancy CM, Kamerow DB. Evidence based medicine meets cost-effectiveness analysis. JAMA. 1996;276(4):329-330. No original analysis. [pmid: 8656547].
Clarke Ann E. Arthritis patient education: how economic evaluations can inform health policy. Can Public Policy. 1997;23:162-176. No decision making.
Claxton K, Culyer AJ. Not a NICE fallacy: a reply to Dr Quigley. J Med Ethics. 2008;34(8):598-601. No original analysis. [pmid: 18667648].
Clement FM, Harris A, Li JJ, Yong K, et al. Using effectiveness and cost-effectiveness to make drug coverage decisions: a comparison of Britain, Australia, and Canada. JAMA. 2009:1437-43. Descriptive only. [pmid: 19809025].
Clement Nee, Shrive FM, Ghali WA, et al. The impact of using different costing methods on the results of an economic evaluation of cardiac care: microcosting vs gross-costing approaches. Health Econ. Apr. 2009;18(4):377-88. Costing study. [pmid: 18615835].
Cline RR, Gupta K. Drug benefit decisions among older adults: A policy-capturing analysis. Med Decis Mak. 2006;26(3):273-281. Limited case study.
Cline RR, Gupta K. Judgment processes in older adults' drug benefit evaluations. Res Social Adm Pharm. 2005;1(1):5-20. No cost effectiveness analysis, Other. [pmid: 17138463].
Cobden DS, Niessen LW, Rutten FF, et al. Modeling the economic impact of medication adherence in type 2 diabetes: a theoretical approach. Patient Prefer Adherence. 2010:283-90. Other. [pmid: 20859455].
Cohen LJ. Looking beyond the formulary budget in cost-benefit analysis. Symposium proceedings. Am J Manag Care. 1997;3:S11-7. Costing study, No decision making. [pmid: 10180337].
Cojocel C, Souetre E, Detsky AS, et al. Using cost-effectiveness analysis for formulary decision-making-from theory into practice-discussion. Pharmacoeconomics. 1994;6(4):286-288. No original analysis.
Colantonio LD, Marti SG, Rubinstein AL. Economic evaluations on cardiovascular preventive interventions in Argentina. Expert Rev Pharmacoecon Outcomes Res. 2010:465-73. Other. [pmid: 20715922].
Colmenero F, Sullivan SD, Palmer JA, et al. Quality of clinical and economic evidence in dossier formulary submissions. Am J Managed Care. 2007;13(7):401-407. Focuses on single condition, Other.
Conrad DA, Deyo RA. Economic decision analysis in the diagnosis and treatment of low back pain: a methodologic primer. Spine. 1994;19(18S):2101S-2106. Methods only. [pmid: 7801189].
Cook SA, Rosser R, Meah S, et al. Clinical decision guidelines for NHS cosmetic surgery: Analysis of current limitations and recommendations for future development. Br J Plast Surg. 2003;56(5):429-436. Does not apply to Economics, No cost effectiveness analysis, Other. [pmid: 12890455].
Cookson R, Drummond M, Weatherly H. Explicit incorporation of equity considerations into economic evaluation of public health interventions. Health Econ Policy Law. 2009:231-245. Other. [pmid: 19216834].
Cookson R, Hutton J. Regulating the economic evaluation of pharmaceuticals and medical devices: a European perspective. Health Policy. 2003;63(2):167-178. No original analysis. [pmid: 12543529].
Cooper LM, Linde-Zwirble W. Cost-effectiveness of drug-eluting stents: Real-world scrutiny of the BASKET trial of real-world usage. Expert Opin. Drug Deliv. 2006;3(3):305-309. No original analysis. [pmid: 16640492].
Cooper N, Coyle D, Abrams K, et al. Use of evidence in decision models: an appraisal of health technology assessments in the UK since 1997. J Health Serv Res Policy. 2005;10(4):245-50. Article of interest, Methods only, No cost effectiveness analysis. [pmid: 16259692].
Coyle D, Welch V, Shea B, et al. Issues of consensus and debate for economic evaluation in rheumatology. J Rheumatol. 2001;28(3):642-7. Not Aim 3 but applies to Aim 2. [pmid: 11296975].
Coyle D. Statistical analysis in pharmacoeconomic studies. A review of current issues and standards. Pharmacoeconomics. 1996;9(6):506-16. Methods only. [pmid: 10160478].
Craig N, Parkin D, Gerard K. Clearing the fog on the Tyne: Programme budgeting in Newcastle and North Tyneside Health Authority. Health Policy. 1995;33(2):107-125. Focuses on single condition, Methods only, No original analysis, Other. [pmid: 10144435].
Crinson I. The politics of regulation within the ‘modernized’ NHS: the case of beta interferon and the ‘cost-effective’ treatment of multiple sclerosis. Crit Soc Pol. 2004;24(1):30-49. Focuses on single condition, No original analysis.
Croghan TW, Johnstone BM, Buesching DP, et al. Information needs for medication coverage decisions in a state Medicaid program. Med Care. 1999;37(4 Suppl Lilly):AS24-31. Methods only, No cost effectiveness analysis, No original analysis. [pmid: 10217390].
Crowe HM, Quintiliani R. Antibiotic formulary selection. Med Clin North Am. 1995;79(3):463-476. No cost effectiveness analysis, No original analysis. [pmid: 7752722].
Currie JM. Choosing among alternative programs for poor children. Future Child. 1997;7(2):113-31. No cost effectiveness analysis, No original analysis, Other. [pmid: 9299840].
Dana WJ, McWhinney B. Managing high cost and biotech drugs: two institutions' perspectives. Hosp Formul. 1994;29(9):638-45. Costing study, Limited case study, No original analysis. [pmid: 10137060].
David Y, Jahnke E. Medical technology management: from planning to application. Conf Proc IEEE Eng Med Biol Soc. 2005;1:186-9. Methods only, No original analysis, Other. [pmid: 17282142].
Davies L, Coyle D, Drummond M. Current status of economic appraisal of health technology in the European Community: report of the network. The EC Network on the Methodology of Economic Appraisal of Health Technology. Soc Sci Med. 1994;38(12):1601-7. Not Aim 3 but applies to Aim 2. [pmid: 8047917].
Davis JC, Robertson MC, Ashe MC, et al. Does a home-based strength and balance programme in people aged =80 years provide the best value for money to prevent falls? A systematic review of economic evaluations of falls prevention interventions. Br J Sports Med. 2010:80-89. Other. [pmid: 20154094].
Davis JL, Knief S. A strategic approach to the introduction of new technology. Soc Sci Med. 2003;9(4):26. No original analysis.
Davis MM. Varicella vaccine, cost-effectiveness analyses, and vaccination policy. JAMA. 2005;294(7):845-6. No original analysis. [pmid: 16106012].
Davis JC, Robertson MC, Comans T, et al. Guidelines for conducting and reporting economic evaluation of fall prevention strategies. Osteoporos Int. 2011:2449-59. [pmid: 21104231].
Deccache A. Evaluating quality and effectiveness in the promotion of health: approaches and methods of public health and social sciences. Promot Educ. 1997;4(2):10-5. Does not apply to Economics, No cost effectiveness analysis, Other. [pmid: 9312335].
Delwel GO, Sprenger MJ. Pharmaco-economic evaluations of new drugs: potential key to a more efficient allocation of the health care budget. Ned Tijdschr Geneeskd. 2002;146(23):1068-71. No original analysis, Other. [pmid: 12085554].
Detsky Allan S. Using cost-effectiveness analysis for formulary decision making: from theory into practice. Pharmacoeconomics. 1994;6(4):281-288. No original analysis. [pmid: 10147465].
Detsky AS, Laupacis A. Relevance of cost-effectiveness analysis to clinicians and policy makers. JAMA. 2007;298(2):221-224. Methods only, No original analysis. [pmid: 17622605].
Deverka PA, Vernon J, McLeod HL. Economic Opportunities and Challenges for Pharmacogenomics. 2010:423-437. Other.
Devlin N, Dakin H, Rice N, et al. NICE's cost-effectiveness threshold revisited: New evidence on the influence of cost-effectiveness and other factors on NICE decisions. Value Health. 2010:A246. No data.
Dietrich ES, Nakashima T, Ahrens S. Pharmacoeconomic studies - usability for reimbursement decisions. Dtsch Med Wochenschr. 2010:333-8. Other. [pmid: 20165996].
Dolan P, Tsuchiya A, Wailoo A. NICE's citizen's council: what do we ask them, and how?. Lancet. 2003;362(9387):918-919. Article of interest, No original analysis. [pmid: 13678989].
Donato R, Segal L. The economics of primary healthcare reform in Australia - towards single fundholding through development of primary care organisations. Aust N Z J Public Health. 2010:613-9. Other. [pmid: 21134065].
Doran CM. Critique of an economic evaluation using the Drummond checklist. Appl Health Econ Health Policy. 2010:357-359. Cannot access article- unsure if includes any sort of economic analysis/evaluation. [pmid: 21043536].
Douw K, Vondeling H, Oortwijn W. Priority setting for horizon scanning of new health technologies in Denmark: views of health care stakeholders and health economists. Health Policy. 2006;76(3):334-345. Does not apply to Economics. [pmid: 16081185].
Dranitsaris G, Leung P. Using decision modeling to determine pricing of new pharmaceuticals: The case of neurokinin-1 receptor antagonist antiemetics for cancer chemotherapy. Int J Technol Assess Health Care. 2004;20(3):289-295. No decision making. [pmid: 15446758].
Dranitsaris G, Pilla NJ, McGreer A. A vancomycin drug use evaluation and economic analysis in a cancer treatment centre. Can J Hosp Pharm. 1994;47(2):59-64. Focuses on single condition, No decision making. [pmid: 10134128].
Drummond M, Barbieri M, Cook J, et al. Transferability of economic evaluations across jurisdictions: ISPOR good research practices task force report. Value Health. 2009:409-418. Focus is on transferability of data only. [pmid: 19900249].
Drummond MF. Health economic-evaluation and reimbursement of pharmaceuticals. Eur J Pharm Sci. 1994;2(1-2):56. No original analysis.
Drummond M, Brown R, Fendrick AM, et al. Use of Pharmacoeconomics information--report of the ISPOR Task Force on use of pharmacoeconomic/health economic information in health-care decision making. Value Health. 2003;6(4):407-16. No original analysis. [pmid: 12859580].
Drummond M, Cooke J, Walley T. Economic evaluation under managed competition: evidence from the U.K. Soc Sci Med. 1997;45(4):583-595. No original analysis. [pmid: 9226783].
Drummond M. Pharmacoeconomics: Friend or foe?. An. Rheum Dis. 2006;65(SUPPL. 3):iii44-iii47. Focuses on single condition, No original analysis.
Drummond MF, Mason AR. European perspective on the costs and cost-effectiveness of cancer therapies. J Clin Oncol. 2007-2008;25(2):191-195. No original analysis. [pmid: 17210939].
Drummond M. Using economic evaluation in reimbursement decisions for health technologies: lessons from international experience. Pharmaceutical Innovation: Incentives, Competition, and Cost-Benefit Analysis in International Perspective. Cambridge University Press. 2007:215-225. No original analysis.
Duintjer Tebbens RJ, Pallansch MA, Cochi SL, et al. Economic analysis of the global polio eradication initiative. Vaccine. 2010:334-43. [pmid: 21029809].
D'Souza AO, Smith MJ, Miller LA, et al. An appraisal of pharmacoeconomic evidence of maintenance therapy for COPD. Chest. 2006;129(6):1693-708. Limited case study, No original analysis,Other. [pmid: 16778291].
Eccles M, Mason J, Freemantle N. Developing valid cost effectiveness guidelines: a methodological report from the north of England evidence based guideline development project. Quality in Health Care. 2000;9(2):127-132. Article of interest, No original analysis. [pmid: 11067251].
Eccles M, Mason J. How to develop cost-conscious guidelines. Health Technology Assess. 2001;5(16):1-78. Methods only, No original analysis.
Economic analysis of health care technology. A report on principles. Task Force on Principles for Economic Analysis of Health Care Technology. Ann Intern Med. 1995;123(1):61-70. Article of interest. [pmid: 7762918].
Eddama O, Coast J. Use of economic evaluation in local health care decision-making in England: A qualitative investigation. Health Policy. 2009:261-270. Other. [pmid: 18657336].
Eddama O, Coast J. A systematic review of the use of economic evaluation in local decision-making. Health Policy. 2008;86(2-3):129-141. No original analysis. [pmid: 18192059].
Eddy DM. Clinical decision making: from theory to practice. Applying cost-effectiveness analysis. The inside story. JAMA. 1992;268(18):2575-2582. No original analysis. [pmid: 1404827].
Eddy DM. Clinical decision making: from theory to practice. Cost-effectiveness analysis. Is it up to the task?. JAMA. 1992;267(24):3342-3348. Does not apply to health or healthcare, No original analysis. [pmid: 1597918].
Eddy D. Bringing health economic modeling to the 21st century. Value Health. 2006;9(3):168-178. No original analysis. [pmid: 16689710].
Edejer TT. Improving the use of research evidence in guideline development: 11. Incorporating considerations of cost-effectiveness, affordability and resource implications. Health Res Policy Syst. 2006:423. Article of interest, No original analysis, Other.
Edgar BS. Shifting the focus from cost to value: a government perspective. J Manag Care Pharm. 2006;12(6 Suppl B):S11-5. quiz S24-6. No cost effectiveness analysis, No original analysis. [pmid: 17274691].
Eisenstein EL, Ortiz M, Anstrom KJ, et al. Assessing the quality of medical information technology economic evaluations: room for improvement. AMIA Annu Symp Proc. 2006:234-8. No original analysis, Other. [pmid: 17238338].
Elshaug AG, Hiller JE, Moss JR. Exploring policy-makers' perspectives on disinvestment from ineffective healthcare practices. Int J Technol Assess. Health Care. 2008;24(1):1-9. No cost effectiveness analysis. [pmid: 18218163].
Elsinga E, Rutten FF. Economic evaluation in support of national health policy: the case of The Netherlands. Soc Sci Med. 1997;45(4):605-20. Methods only, No original analysis. [pmid: 9226785].
Elston J, Stein K. A rapid needs assessment of the provision of Health Technology Assessment in the south-west peninsula. J Public Health. 2007;29(2):157-164. Does not apply to Economics.
Esperato A, Garcia-Altes A. Health promotion: a profitable investment? Economic efficiency of preventive interventions in Spain. Gac Sanit. 2007;21(2):150-61. No original analysis, Other. [pmid: 17419933].
Essers BA, Seferina SC, Tjan-Heijnen VC, et al. Transferability of model-based economic evaluations: the case of trastuzumab for the adjuvant treatment of HER2-positive early breast cancer in the Netherlands. Value Health. 2010:375-80. Other. [pmid: 20088894].
Evans S, Weir D. Decision making in wound care: are we being cost effective?. Care Management. 2000;6(5):10. No original analysis.
Evers S, Goossens M, de Vet H, et al. Criteria list for assessment of methodological quality of economic evaluations: consensus on health economic criteria. Int J Technol Assess Health Care. 2005;21(2):240-5. Article of interest. [pmid: 15921065].
Farquhar Irina, Summers Kent, Sorkin Alan, et al. Investing in health: The social and economic benefits of health care innovation. Research in Human Capital and Development. 2001;(14). No original analysis, Other.
Faucheux S, Froger G. Decision-Making under Environmental Uncertainty. 2001:492-505. Does not apply to health or healthcare.
Ferconio S, Yoder L, Charland K. Managing the business of ambulatory care: the impact of reimbursement systems on hospital operations. Journal of AHIMA. 1993;64(6):85-90. No original analysis. [pmid: 10126380].
Ferrusi IL, Leighl NB, Kulin NA. Do economic evaluations of targeted therapy provide support for decision makers?. J Oncol Pract. 2011:36s-45s. Other. [pmid: 21886518].
Franken M, Sandmann F, Koopmanschap M. Cost-effectiveness in drug reimbursement decision making: A toothless tiger?. Value Health. 2011:A352. Other.
Fry RN, Avey SG, Sullivan SD. The Academy of Managed Care Pharmacy Format for Formulary Submissions: an Evolving Standard - a Foundation for Managed Care Pharmacy Task Force Report. Value in Health. 2003;6(5):505-521. Article of interest, No original analysis. [pmid: 14627057].
Furniss J. PPRS: Not dead yet. BMJ. 2008 Feb 2;336(7638):251-4. BMJ. 2008;336(7641):406. No original analysis. [pmid: 18292147].
Gabriel S, Drummond M, Maetzel A, et al. OMERACT 6 Economics Working Group report: A proposal for a reference case for economic evaluation in rheumatoid arthritis. J. Rheumatol. 2003;30(4):886-890. Article of interest, No original analysis. [pmid: 12672223].
Gafni A, Birch S. Guidelines for the adoption of new technologies: a prescription for uncontrolled growth in expenditures and how to avoid the problem. CMAJ. 1993;148(6):913-7. Does not apply to Economics, No cost effectiveness analysis, No original analysis. [pmid: 8448705].
Galani C, Rutten FF. Self-reported healthcare decision-makers' attitudes towards economic evaluations of medical technologies. Curr Med Res Opin. 2008. Does not apply to Economics, Does not apply to health or healthcare.
Galt KA, Rich EC, Kralewski JE, et al. Group practice strategies to manage pharmaceutical cost in an HMO network. Am J Manag Care. 2001;7(11):1081-90. Cost predictors only, Costing study. [pmid: 11725811].
Gambhir SS, Schwimmer J. Economic evaluation studies in nuclear medicine: a methodological review of the literature. Q J Nucl Med. 2000;44(2):121-37. Article of interest, No original analysis. [pmid: 10967623].
Gandjour A, Lauterbach KW. Allocating resources in health care: a comparison of cost-effectiveness analyses and evidence-based medicine. Eur J Health Econ. 2000;1(2):116-121. No original analysis, Other.
Garattini L, Cornago D, De Compadri P. Pricing and reimbursement of in-patent drugs in seven European countries: a comparative analysis. Health Policy. 2007;82(3):330-9. Methods only, No original analysis, Other. [pmid: 17125881].
Garber AM, Phelps CE. Economic foundations of cost-effectiveness analysis. J Health Econ. 1997;16(1):1-31. Methods only. [pmid: 10167341].
Garcia-Altes A, Jovell E. Economic analysis of treatment of functional dyspepsia. An assessment of the quality of published studies. Int J Technol Assess Health Care. 2001;17(4):517-27. Article of interest, No original analysis, Other. [pmid: 11758296].
Gardner DM, MacKinnon N, Langille DB, et al. A comparison of factors used by physicians and patients in the selection of antidepressant agents. Psychiatr Serv. 2007;58(1):34-40. Costing study, Does not apply to Economics, No original analysis. [pmid: 17215410].
Gardner J. HCFA revives proposal for cost-effectiveness rule. Mod Healthc. 1996;26(18):70. No original analysis.
Gaspoz JM, Kennedy JW, Orav EJ, et al. Cost-effectiveness of prescription recommendations for cholesterol-lowering drugs: a survey of a representative sample of American cardiologists. J Am Coll Cardiol. 1996;27(5):1232-7. Article of interest. [pmid: 8609348].
Gavaza P, Rascati K, Brown C, et al. The state of health economic and pharmacoeconomic evaluation research in Zimbabwe: A review. Curr Ther Res Clin Exp. 2008;69(3):268-285. No original analysis.
Giacomini MK, Cook DJ, Streiner DL, et al. Using Practice Guidelines to Allocate Medical Technologies - an Ethics Framework. Int J Technol Assess Health Care. 2000;16(4):987-1002. Does not apply to Economics. [pmid: 11155847].
Giacomini MK. The which-hunt: assembling health technologies for assessment and rationing. including commentary by Tanenbaum SJ and Cushman R. J Health Polit Policy Law. 1999;24(4):715-768. Does not apply to Economics, No cost effectiveness analysis, No original analysis. [pmid: 10503155].
Gibson J, Mitton C, Martin D, et al. Ethics and economics: does programme budgeting and marginal analysis contribute to fair priority setting?. J Health Serv Res Policy. 2006;11(1):32-7. Limited case study, Methods only, No cost effectiveness analysis, No original analysis. [pmid: 16378530].
Gillick MR. Sounding board. Medicare coverage for technological innovations--time for new criteria?. N Engl J Med. 2004;350(21):2198-2203. No original analysis, Other.
Glassman PA, Model KE, Kahan JP, et al. The role of medical necessity and cost-effectiveness in making medical decisions. Ann Intern Med. 1997;126(2):152-156. Methods only, No original analysis. [pmid: 9005750].
Goeree R, Levin L. Building bridges between academic research and policy formulation: the PRUFE framework - an integral part of Ontario's evidence-based HTPA process. Pharmacoeconomics. 2006;24(11):1143-56. Article of interest, Does not apply to Economics, Limited case study, Other. [pmid: 17067198].
Goetghebeur MM, Rindress D. Towards a European consensus on conducting and reporting health economic evaluations--a report from the ISPOR Inaugural European Conference. Value Health. 1999;2(4):281-7. Methods only, No original analysis. [pmid: 16674318].
Gold MR, Sofaer S, Slegelberg T. Medicare and cost-effectiveness analysis: time to ask the taxpayers. Health Affairs. 2007;26(5):1399-1406. No decision making, No original analysis. [pmid: 17848451].
Gold M. Panel on cost-effectiveness in health and medicine. Med Care. 1996;34(12):DS197-DS199. No original analysis. [pmid: 8969326].
Gold MR. Tea, biscuits, and health care prioritizing. Health Affairs. 2005;24(1):234-239. Article of interest, No cost effectiveness analysis, No original analysis. [pmid: 15647235].
Goldfarb NI, Phillips A, Conn M, et al. Economic and health outcomes of capsule endoscopy: opportunities for improved management of the diagnostic process for obscure gastrointestinal bleeding. Dis Manag. 2002;5(3):123-135. Focuses on single condition, No original analysis, Other.
Goldie SJ. Chapter 15: Public health policy and cost-effectiveness analysis. J Natl Cancer Inst Monogr. 2003;(31):102-110. No original analysis. [pmid: 12807953].
Gordon J, Karnon J. Health technology appraisal of new drugs: Are we getting it right?. Value Health. 2011:A501. Evaluates difference between how drugs are approved and how they are actually used at clinical level.
Gorham Peter. Cost-Effectiveness Guidelines: The Experience of Australian Manufacturers. Pharmacoeconomics. 1995;8(5):369-373. Does not apply to Economics, No original analysis. [pmid: 10160071].
Gostin LO, Kim SC. Ethical allocation of preexposure HIV prophylaxis. JAMA: Journal of the American Medical Association. 2011-2012:191-192. Other.
Grabowski H, Mullins CD. Pharmacy benefit management, cost-effectiveness analysis and drug formulary decisions. Soc Sci Med. 1997;45(4):535-544. No original analysis. [pmid: 9226779].
Grabowski H. The role of cost-effectiveness analysis in managed-care decisions. Pharmacoeconomics. 1998;14:15-24. Focuses on single condition, No original analysis. [pmid: 10186477].
Graf von, der Schulenburg JM. Economic evaluation of medical technologies: from theory to practice--the German perspective. Soc Sci Med. 1997;45(4):621-33. No original analysis. [pmid: 9226786].
Graf von der Schulenburg JM, Hoffmann C. Review of European guidelines for economic evaluation of medical technologies and pharmaceuticals. Eur J Health Econ. 2000;1(1):2-8. Article of interest, No original analysis.
Granata AV, Hillman AL. Competing practice guidelines: using cost-effectiveness analysis to make optimal decisions. Ann Intern Med. 1998;128(1):56-63. Methods only. [pmid: 9424982].
Green JA, Williams C, Cribb A, et al. Fair and effective resource allocation in cancer care: uncharted territory?. Health Care Anal. 1996;4(1):19-28. No original analysis, Other. [pmid: 10158435].
Griffin S, Claxton K, Sculpher M. Decision analysis for resource allocation in health care. J Health Serv Res Policy. 2008;13(Suppl):323-30. Does not apply to Economics, Methods only.
Grosse SD, Teutsch SM, Haddix AC. Lessons from cost-effectiveness research for United States public health policy. Annu Rev Public Health. 2007;28:365-91. No original analysis. [pmid: 17222080].
Gunther OH, Konig HH. Decision makers' and scientists' opinion about contingent valuation and choice experiments for measuring willingness to pay in health care: Results from a survey in Germany. Int J Technol Assess Health Care. 2006;22(3):351-361. Methods only. [pmid: 16984064].
Gyrd-Hansen D. Cost-benefit analysis of mammography screening in Denmark based on discrete ranking data. Int J Technol Assess Health Care. 2000;16(3):811-21. No cost effectiveness analysis, Other. [pmid: 11028136].
Gyrd-Hansen D. Willingness to pay for a qaly - theoretical and methodological issues. Pharmacoeconomics. 2005;23(5):423-432. Methods only, No original analysis. [pmid: 15896094].
Hadorn DC. The Oregon priority-setting exercise: quality of life and public policy. Hastings Cent Rep. 1991;21(3):S11-6. No original analysis, Other. [pmid: 11642898].
Hagen MD, Garber AM, Goldie SJ, et al. Does cost-effectiveness analysis make a difference? .Lessons from Pap smears. Med Decis Making. 2001;21(4):307-323. No decision making, No original analysis, Other. [pmid: 11475387].
Hahn RW, Kosec K, Neumann PJ, et al. What affects the quality of economic analysis for life-saving investments?. Risk Anal. 2006;26(3):641-55. No original analysis, Other. [pmid: 16834624].
Hahn Robert W, Tetlock Paul C. Has economic analysis improved regulatory decisions?. J Econ Perspect. 2008;22(1):67-84. Does not apply to healt or healthcare, Methods only.
Hailey D. Australian Economic Evaluation and Government Decisions on Pharmaceuticals, Compared to Assessment of Other Health Technologies. Soc Sci Med. 1997;45(4):563-581. Methods only, Other. [pmid: 9226782].
Hall J. From Research to Action: does economic evaluation affect health policy or practice?. Economics and health:1993: Proceedings of the Fifteenth Australian Conference of Health Economists. 1994:244-252. No original analysis, Other.
Hansson SO. Philosophical Problems in Cost-Benefit Analysis. Econ Philos. 2007;23(2):163-183. Does not apply to Economics, Does not apply to health or healthcare, Methods only, No original analysis.
Hansson SO. Social decisions about risk and risk-taking. Soc Choice Welfare. 2007;29(4):649-663. Does not apply to Economics.
Harrison FG, Kuhlemeier KA. How do skilled nursing rehabilitation managers track efficiency and costs?. J Allied Health. 2001;30(1):43-47. No original analysis. [pmid: 11265273].
Hartz S, John J. Contribution of economic evaluation to decision making in early phases of product development: a methodological and empirical review. Int J Technol Assess Health Care. 2008;24(4):465-72. No original analysis. [pmid: 18828942].
Hasman A, McIntosh E, Hope T. What reasons do those with practical experience use in deciding on priorities for healthcare resources? A qualitative study. J Med Ethics. 2008;34(9):658-63. Does not apply to Economics, No cost effectiveness analysis, Other. [pmid: 18757635].
Hastings J, Adams EJ. Joint project of the international network of agencies for health technology assessment--Part 1: Survey results on diffusion, assessment, and clinical use of positron emission tomography. Int J Technol Assess Health Care. 2006;22(2):143-8. Does not apply to Economics, No original analysis, Limited case study, No cost effectiveness analysis. [pmid: 16571188].
Haws RA, Thomas AL, Bhutta ZA, et al. Impact of packaged interventions on neonatal health: a review of the evidence. Health Policy Plan. 2007;22(4):193-215. Does not apply to Economics, No original analysis. [pmid: 17526641].
Hay JW. The application of cost-effectiveness and cost-benefit analysis to pharmeceuticals. Cambridge and New York. Cambridge University Press. 2005:225-247. Article of interest, No cost effectiveness analysis, No decision making, No original analysis.
Hearns G, Klein MC, Trousdale W, et al. Development of a support tool for complex decision-making in the provision of rural maternity care. Health Policy. 2010:82-96. Other. [pmid: 19963298].
Heidenberger K, Roth M. Taxonomies in the strategic management of health technology: the case of multiperiod compartmental hiv/aids policy models. Int J Technol Manag. 1998;15(3-5):336-358. Does not apply to Economics, Limited case study, No original analysis.
Helfand M, Mahon SM, Eden KB, et al. Screening for skin cancer. Am J Prev Med. 2001;20(3 Suppl):47-58. Does not apply to Economics, No cost effectiveness analysis. [pmid: 11306232].
Henriksson M, Palmer S, Chen R, et al. Assessing the cost effectiveness of using prognostic biomarkers with decision models: case study in prioritizing patients waiting for coronary artery surgery. BMJ (Overseas and Retired Doctors Edition). 2010:b5606. Other.
Henry D, Lopert R. Pharmacoeconomics and policy decisions: the Australian health care system. Clin Ther. 1999;21(5):909-915. No original analysis. [pmid: 10397384].
Henry D. Economic analysis as an aid to subsidisation decisions: the development of Australian guidelines for pharmaceuticals. Pharmacoeconomics. 1992;1(1):54-67. No original analysis. [pmid: 10147039].
Hepburn VA, Eger R, Kim J, et al. Structuring a framework for public health performance-based budgeting: a Georgia case study. J Public Health. Management and Practice. 2007;13(2):173-179. Costing study, No cost effectiveness analysis, Other.
Hinman AR. Quantitative policy analysis and public health policy: a macro and micro view. Am J Prev Med. 1997;13(1):6-11. Methods only, No original analysis. [pmid: 9037336].
Hirth RA, Chernew ME, Miller E, et al. Willingness to pay for a quality-adjusted life year: in search of a standard. Med Decis Making. 2000;20(3):332-342. No original analysis. [pmid: 10929856].
Hjelmgren J, Berggren F, Andersson F. Health economic guidelines--similarities, differences and some implications. Value Health. 2001;4(3):225-50. Does not apply to Economics. [pmid: 11705185].
Hoel M. What Should (Public) Health Insurance Cover?. J Health Econ. 2007;26(2):251-262. No original analysis. [pmid: 16978719].
Hoomans T, Severens JL, van der Roer N, et al. Methodological quality of economic evaluations of new pharmaceuticals in the Netherlands. Pharmacoeconomics. 2011. Checklist borrowed from another source, not an original guideline.
Hoomans T, Fenwick EA, Palmer S, et al. Value of information and value of implementation: application of an analytic framework to inform resource allocation decisions in metastatic hormone-refractory prostate cancer. Value Health. 2008. No decision making.
Hoomans T, Ament AJ, Evers SM, et al. Implementing guidelines into clinical practice: what is the value?. J Eval Clin Pract. 2011:606-14. [pmid: 21029273].
Hornberger J, Covington M, Luo R, et al. Integrated economic evaluation of enfuvirtide (enf) in the us using a combination of cost-effectivenes analysis (cea) and budget impact analysis (bia) to enhance health care decision-making. Value Health. 2003;6(6):625. Focuses on single condition, Other.
Hornberger J, Holodniy M, Robertus K, et al. A systematic review of cost-utility analyses in HIV/AIDS: implications for public policy. Med Decis Making. 2007;27(6):789-821. No decision making. [pmid: 18057191].
Hounton SH, Akonde A, Zannou DM, et al. Costing universal access of highly active antiretroviral therapy in Benin. AIDS Care. 2008;20(5):5827. Costing study.
Hoyle M. Future drug prices and cost-effectiveness analyses. Pharmacoeconomics. 2008;26(7):589-602. Article of interest. [pmid: 18563950].
Hutton J, Brown RE. Use of economic evaluation in decision making: what needs to change?. Value Health. 2002;5(2):65-6. No decision making, No original analysis. [pmid: 11918820].
Hutubessy R, Henao AM, Namgyal P, et al. Results from evaluations of models and cost-effectiveness tools to support introduction decisions for new vaccines need critical appraisal. BMC Med. 2011:55. Other. [pmid: 21569407].
Hutubessy RC, Bendib LM, Evans DB. Critical issues in the economic evaluation of interventions against communicable diseases. Acta Trop. 2001;78(3):191-206. Methods only, No original analysis, Other. [pmid: 11311183].
Iglehart JK. Health care reform. The labyrinth of Congress. N Engl J Med. 1993;329(21):1593-1596. No original analysis. [pmid: 8413495].
Ikegami N, Drummond M, Fukuhara S, et al. Why has the use of health economic evaluation in Japan lagged behind that in other developed countries?. Pharmacoeconomics. 2002;20(Suppl):21-7. Article of interest, No original analysis, Other. [pmid: 12036381].
Indritz MES, Artz M. When cost is a consideration: Using decision analysis for formulary recommendations. P T. 1999;24(8):368-382. No original analysis.
Intrator O, Mor V. Effect of state Medicaid reimbursement rates on hospitalizations from nursing homes. J Am Geriatr Soc. 2004;52(3):393-398. Does not apply to Economics, Does not apply to health or healthcare. [pmid: 14962154].
Iskedjian M, Trakas K, Bradley CA, et al. Quality assessment of economic evaluations published in pharmacoeconomics - the first four years (1992 to 1995). Pharmacoeconomics. 1997;12(6):685-694. Not Aim 3 but applies to Aim 2. [pmid: 10175980].
Jacobs P, Bachynsky J, Baladi JF. A comparative review of pharmacoeconomic guidelines. Pharmacoeconomics. 1995;8(3):182-189. Article of interest, Methods only. [pmid: 10155616].
Jacobson PD, Kanna ML. Cost-effectiveness analysis in the courts: recent trends and future prospects. J Health Polit Policy Law. 2001;26(2):291-326. No original analysis. [pmid: 11330082].
James C, Carrin G, Savedoff W, et al. Clarifying efficiency-equity tradeoffs through explicit criteria, with a focus on developing countries. Health Care Anal. 2005;13(1):33-51. No original analysis. [pmid: 15889680].
Jan Stephen. Why does economic analysis in health care not get implemented more? Towards a greater understanding of the rules of the game and the costs of decision making. Appl Health Econ Health Policy. 2003;2(1):17-24. No original analysis. [pmid: 14619270].
Jarrett J, Mugford M. Genetic health technology and economic evaluation: a critical review. Appl Health Econ Health Policy. 2006;5(1):27-35. Methods only, No original analysis. [pmid: 16774290].
Jefferson T, King JE. Can Post Keynesians make better use of behavioral economics?. Journal of Post Keynesian Economics. 2010:211-234. Other.
Jiang HJ, Lagasse RS, Ciccone K, et al. Factors influencing hospital implementation of acute pain management practice guidelines. J Clin Anesth. 2001;13(4):268-76. Does not apply to Economics, No cost effectiveness analysis. [pmid: 11435051].
Jimenez DJ, Bastias SG. The scope of economic evaluation of healthcare interventions. Revista Medica De Chile. 2010:71-75. Other.
Jit M, Stagg HR, Aldridge RW, et al. Dedicated outreach service for hard to reach patients with tuberculosis in London: observational study and economic evaluation. BMJ. 2011:732. Limited discussion of decision making.
Johri M, Lehoux P. The great escape? Prospects for regulating access to technology through health technology assessment. Int J Technol Assess Health Care. 2003;19(1):179-93. Does not apply to Economics, Methods only, No original analysis. [pmid: 12701950].
Jones H. Bayesian analysis: an objective, scientific approach to better decisions. Clin Lab Manage. Rev. 1999;13(3):148-153. Methods only, No original analysis. [pmid: 10557877].
Jonsson B. Economic evaluation of medical technologies in Sweden. Soc Sci Med. 1997;45(4):597-604. No original analysis. [pmid: 9226784].
Kanavos P, Mossialos E. Outstanding regulatory aspects in the European pharmaceutical market. Pharmacoeconomics. 1999;15(6):519-533. No original analysis, Other. [pmid: 10538326].
Kannry J, Mukani S, Myers K. Using an evidence-based approach for system selection at a large academic medical center: lessons learned in selecting an ambulatory EMR at Mount Sinai Hospital. J Healthc Inf Manag. 2006;20(2):84-99. Does not apply to Economics, Limited case study. [pmid: 16669592].
Kapiriri L, Norheim OF, Heggenhougen K. Public participation in health planning and priority setting at the district level in Uganda. Health Policy Plan. 2003;18(2):205-213. Does not apply to Economics, No cost effectiveness analysis. [pmid: 12740325].
Karnon J, Vanni T. Calibrating models in economic evaluation: a comparison of alternative measures of goodness of fit, parameter search strategies and convergence criteria. Pharmacoeconomics. 2011:51-62. Other. [pmid: 21142278].
Karnon J, Brennan A, Akehurst R. Decision modeling to inform decision making: seeing the wood for the trees. Med Decis Making. 2010:E20-2. LTE. [pmid: 20489217].
Kauf TL. Methodological concerns with economic evaluations of meningococcal vaccines. Pharmacoeconomics. 2010:449-61. Other. [pmid: 20465314].
Keaney M. Can economics be bad for your health?. Health Care Anal. 1997;5(4):299-305. Methods only, Other. [pmid: 10177943].
Kenkel DS, Manning W. Economic evaluation of nutrition policy or, there's no such thing as a free lunch. Food Policy. 1999;24(2-3):145-162. Does not apply to Economics, Does not apply to healt or healthcare.
Kernick D. Costing interventions in primary care. Fam Pract. 2000;17(1):66-70. Cost predictors only, Other. [pmid: 10673493].
Kezirian EJ, Yueh B. Accuracy of terminology and methodology in economic analyses in otolaryngology. Otolaryngol Head Neck Surg. 2001;124(5):496-502. Methods only. [pmid: 11337651].
Kirkdale R, Krell J, Brown CO, et al. The cost of a QALY. QJM. 2010:715-20. This is a commentary. [pmid: 20519275].
Knetsch Jack L. Gains, Losses, and the US-EPA economic analyses guidelines: a hazardous product?. J Environ Econ Manage. 2005;32(1):91-112. No original analysis.
Knox S. Health economic decision making in Europe: a new priority for breast cancer advocacy. Breast. 2009:71-72. Other. [pmid: 19380086].
Kolominsky-Rabas PL, Caro JJ. The Hanover Consensus: helpful for German decision-makers?. Value Health. 2008;11(4):545-546. No original analysis. [pmid: 18489522].
Koopmanschap Marc A. Cost-of-Illness Studies: Useful for Health Policy?. Pharmacoeconomics. 1998;14(2):143-148. Methods only, No original analysis.
Kruper L, Kurichi JE, Sonnad SS. Methodologic quality of cost-effectiveness analyses of surgical procedures. Ann Surg. 2007;245(1):147-51. Methods only, No original analysis, Other. [pmid: 17197978].
Kulsomboon V, Palumbo FB, Mullins CD. Criteria to request pharmacoeconomic data and data sources for hospital formulary decisions. Drug Inf J. 2001;35(1):231-240. Article of interest, No original analysis.
Langfitt JT. Cost evaluations in epilepsy: an update. Epilepsia. Suppl 2. 2000;41:S62-8. Costing study. [pmid: 10885741].
Latham SR. Pharmaceutical costs: an overview and analysis of legal and policy responses by the states. J Leg Med. 2003;24(2):141-173. No original analysis, Other. [pmid: 12775406].
Laupacis A, Feeny D, Detsky AS, et al. Tentative guidelines for using clinical and economic evaluations revisited. CMAJ. 1993;148(6):927-9. No original analysis. [pmid: 8448707].
Laupacis A. Economic evaluations in the Canadian common drug review. Pharmacoeconomics. 2006;24(11):1157-1162. No original analysis. [pmid: 17067199].
Laupacis A. Incorporating economic evaluations into decision-making: the Ontario experience. Med Care. 2005;43(7 Suppl):15-9. No original analysis. [pmid: 16056004].
Lave LB. Benefit-Cost Analysis: do the benefits exceed the costs?. Ogus A, editor. Regulation, economics and the law. Elgar, Edward Publishing, Inc. 2001:441-471. Methods only, No original analysis.
Lave Lester B. Benefit-cost analysis: do the benefits exceed the costs?. Risks, costs, and lives saved: Getting better results from regulation. New York and Oxford. Oxford University Press. Washington, D.C. AEI Press. 1996:104-134. Methods only, No original analysis.
Lee TJ. Use of economic evaluation in the listing and pricing of pharmaceuticals. J Prev Med Public Health. 2008;41(2):69-73. Other. [pmid: 18385545].
Le Goff-Pronost Myriam, Sicotte Claude. The added value of thorough economic evaluation of telemedicine networks. Eur J Health Econ. 2010:45-55. Other. [pmid: 19562393].
Legood R, McInnes E. Pressure ulcers: guideline development and economic modelling. J Adv Nurs. 2005;50(3):307-314. No cost effectiveness analysis. [pmid: 15811110].
Lens MB, Dawes M. Economic evaluation in evidence-based practice. Expert Opin Pharmacother. 2002;3(9):1239-43. No original analysis. [pmid: 12186616].
Lin WC, Yen AMF, Chang CM, et al. Computer-aided system for health economic evaluation. J Eval Clin Pract. 2009:797-803. Other. [pmid: 19811591].
Lim ME, Bowen JM, O'Reilly D, et al. Impact of the 1997 Canadian guidelines on the conduct of Canadian-based economic evaluations in the published literature. Value Health. 2010:328-34. Other. [pmid: 19804434].
Lipsy RJ. Institutional formularies: the relevance of pharmacoeconomic analysis to formulary decisions. Pharmacoeconomics. 1992;1(4):265-281. No original analysis, Other. [pmid: 10147017].
Liss P. Hard choices in public health: the allocation of scarce resources. Scandinavian J Public Health. 2003;31(2):156-157. No original analysis.
Lofroth E, Lindholm L, Wilhelmsen L, et al. Optimising health care within given budgets: primary prevention of cardiovascular disease in different regions of Sweden. Health Policy. 2006;75(2):214-229. Does not apply to Economics, Does not apply to health or healthcare. [pmid: 16005539].
Longo CJ. Choices of methodology in pharmacoeconomic studies. Med Care. 1999;37(4):AS32-AS35. No decision making. [pmid: 10217391].
Lopez-Bastida J, Oliva J, Antonanzas F, et al. Spanish recommendations on economic evaluation of health technologies. Eur J Health Econ. 2010:513-20. Other. [pmid: 20405159].
Loubiere S, Moatti JP. Economic evaluation of point-of-care diagnostic technologies for infectious diseases. Clin Microbiol Infect. 2010:1070-6. Other. [pmid: 20670289].
Lovatt B. The United Kingdom guidelines for the economic evaluation of medicines. Med Care. 1996;34(12 Suppl):DS179-81. No original analysis. [pmid: 8969324].
Lovei L. An approach to the economic analysis of water supply projects. Infrastructure and Urban Development Dept. World Bank. 1992. Does not apply to health or healthcare.
Lundin D, Carlsson P, Levin LA, et al. Guidelines of the pharmaceutical benefits board for health economics evaluations. Cost-efficiency analysis from a national perspective. Lakartidningen. 2006;103(47):3716-8. Other. [pmid: 17212321].
Lundkvist J. Pricing and reimbursement of drugs in Sweden. Eur J Health Econ. 2002;3(1):66-70. Article of interest, No cost effectiveness analysis, No original analysis, Other. [pmid: 15609120].
Lyman GH, Kuderer NM. A primer in prognostic and predictive models: development and validation of neutropenia risk models. Support Cancer Ther. 2005;2(3):168-75. Does not apply to Economics, No original analysis. [pmid: 18628168].
Maharaj R. Adding cost to number needed to treat: the COPE statistic. Evid Based Med. 2007;12(4):101-102. Costing study, No cost effectiveness, No original analysis. [pmid: 17885150].
Malin JL, Keeler E, Wang C, et al. Using cost-effectiveness analysis to define a breast cancer benefits package for the uninsured. Breast Cancer ResTreat. 2002;74(2):143-53. No decision making.
Manca A, Willan AR. ‘lost in Translation’ - Accounting for Between-Country Differences in the Analysis of Multinational Cost-Effectiveness Data. Pharmacoeconomics. 2006;24(11):1101-1119. Methods only. [pmid: 17067195].
Manning WG. Panel on cost-effectiveness in health and medicine recommendations: identifying costs. J Clin Psychiatry. 1999;60(Suppl):354-6. discussion 57-8. Methods only.
Marlink R, Forsythe S, Bertozzi SM, et al. Re: This special issue of AIDS--a mix of recent economic analyses and commentary on how best to distill economic insights to improve HIV/AIDS policies and programmes. AIDS. Suppl 1. 2008;22:S1-4. No original analysis. [pmid: 18664940].
Martin A, Jones A, Mugford M, et al. Methods used to identify and measure resource use in economic evaluations: a systematic review of questionnaires for older people. Health Econ. 2011.
Martin EG, Paltiel AD, Walensky RP, et al. Expanded HIV screening in the United States: what will it cost government discretionary and entitlement programs? A budget impact analysis. Value Health. 2010:893-902. Looks at economics of HIV screening program- no decision making component. [pmid: 20950323].
Martin DK, Hollenberg D, Macrae S, et al. Priority setting in a hospital drug formulary: a qualitative case study and evaluation. Health Policy. 2003;66(3):295-303. Does not apply to Economics. [pmid: 14637013].
Mason A, Drummond M, Ramsey S, et al. Comparison of anticancer drug coverage decisions in the United States and United kingdom: does the evidence support the rhetoric?. J Clin Oncol. 2010:3234-3238. Other. [pmid: 20498408].
Mason Fnmj, Eccles M, Freemantle N, et al. A framework for incorporating cost-effectiveness in evidence-based clinical practice guidelines. Health Policy. 1999;47(1):37-52. No original analysis. [pmid: 10387809].
Mason H, Jones-Lee M, Donaldson C. Modelling the monetary value of a QALY: a new approach based on UK data. Health Econ. 2008. Methods only.
Matusewicz W, Baran J, Farkowski MM. Utilizing evidence from different levels in the reimbursement process of new medical technologies-advanced renal cell carcinoma first line therapy in Poland 2008-2009. Value Health. 2010:A217. Cost effectiveness in policy making in Poland dependent on WHO guidelines.
Mauskopf JA, Cates SC, Griffin AD. A pharmacoeconomic model for the treatment of influenza. Pharmacoeconomics. 1999:1673-84. Costing study, Focuses on single condition.
Maynard A. Competition and quality: rhetoric and reality. Int J Qual Health Care. 1998;10(5):379-384. No original analysis. [pmid: 9828026].
McElwee NE, Ho SY, McGuigan KA, et al. Evidence-based coverage decisions? Primum non nocere. Health Aff. (Millwood). 2006;25(4):W279-82. No original analysis. [pmid: 16757489].
McGivney WT. Technology assessment and coverage decision making. AAPPO J. 1994;4(5):11. No decision making, No original analysis. [pmid: 10150666].
McIntosh E, Luengo-Fernandez R. Economic evaluation. Part 2: Frameworks for combining costs and benefits in health care. J Fam Plann Reprod Health Care. 2006;32(3):176-180. Methods only. [pmid: 16857073].
Mcmillan K. Considerations in the Formulary Selection of Hydroxymethylglutaryl Coenzyme a Reductase Inhibitors. Am J Health Syst Pharm. 1996;53(18):2206-2214. Focuses on single condition, No decision making. [pmid: 8879334].
Medicare private health plans versus Medicare savings programs: which is the better way to help people with low incomes afford health care?. reprinted and adapted for the Care Management Journals with permission from the Medicare Rights Center. Care Manag J. 2010:58-65. Other. [pmid: 20426321].
Menon D, Topfer LA. Health technology assessment in Canada: A decade in review. Int. J. Technol. Assess. Health Care. 2000;16(3):896-902. No original analysis, Other. [pmid: 11028144].
Milne R, Clegg A, Stevens A. HTA responses and the classic HTA report. J Public Health. Medicine. 2003;25(2):102-106. Methods only, No original analysis, Other.
Minkoff NB. Multiple vaccines: How do we choose?. J. Managed Care Pharm. 2007;13(7 SUPPL.):S16-S20. Does not apply to Economics, Methods only, No original analysis.
Moore NH. Effects of evidence-based formulary restrictions at a Veterans Affairs medical center. Formulary. 2006;41(12):657-668. Focuses on single condition, No decision making.
Motheral BR, Grizzle AJ, Armstrong EP, et al. Role of Pharmacoeconomics in drug benefit decision-making: results of a survey. Formulary. 2000;35(5):412. No original analysis.
Mshana S, Shemilu H, Ndawi B, et al. What do district health planners in Tanzania think about improving priority setting using ‘accountability for reasonableness’?. BMC Health Serv Res. 2007;7:180. Does not apply to Economics. [pmid: 17997824].
Murphy J, Morris K. Accounting for care: healthcare resource groups for paediatric critical care. Paediatr Nurs. 2008;20(1):37-39. Cost predictors only, Does not apply to Economics, Methods only, No cost effectiveness analysis, No original analysis. [pmid: 18335904].
Nair KV, Ascione FJ. Evaluation of P and T Committee performance: an exploratory study. Formulary. 2001;36(2):136. Does not apply to Economics, No cost effectiveness analysis.
Naylor CD, Williams JI, Basinski A, et al. Technology assessment and cost-effectiveness analysis: misguided guidelines?. CMAJ. 1993;148(6):921-924. Methods only, No decision making, No original analysis. [pmid: 8448706].
Neumann PJ, Johannesson M. From principle to public policy: using cost-effectiveness analysis. Health Aff (Millwood). 1994;13(3):206-14. Article of interest, No original analysis. [pmid: 7927151].
Neumann PJ, Lin PJ, Greenberg D, et al. Do drug formulary policies reflect evidence of value?. Am J Manag Care. 2006;12(1):30-6. No decision making. [pmid: 16402886].
Neumann PJ, Rosen AB, Weinstein MC. Medicare and cost-effectiveness analysis. N Engl J Med. 2005;353(14):1516-22. No original analysis. [pmid: 16207857].
Neumann PJ, Zinner DE, Wright JC. Are methods for estimating QALYs in cost-effectiveness analyses improving?. Med Decis Making. 1997;17(4):402-8. Article of interest, Methods only, No decision making, No original analysis. [pmid: 9343798].
Neumann PJ. The arrival of economic evidence in managed care formulary decisions - the unsolicited request process. Med Care. 2005;43(7):27-32. Article of interest, No original analysis. [pmid: 16056006].
Neumann PJ. Why don't Americans use cost-effectiveness analysis?. Am J Manag Care. 2004;10(5):308-12. No original analysis. [pmid: 15152700].
Neumann PJ, Palmer JA, Daniels N, et al. A strategic plan for integrating cost-effectiveness analysis into the US healthcare system. Am J Manag Care. 2008;14(4):185-188. Article of interest, No original analysis. [pmid: 18402510].
Neumann PJ, Rosen AB, Weinstein MC. Sounding board. Medicare and cost-effectiveness analysis. N Engl J Med. 2005;353(14):1516-1522. Article of interest, No original analysis, Other. [pmid: 16207857].
Neumann PJ. Emerging lessons from the drug effectiveness review project. Health Affairs. 2006;25(4):W262-71. No original analysis. [pmid: 16757486].
Nichol MB, Knight TK, Epstein J, et al. Opinions regarding the academy of managed care pharmacy dossier submission guidelines: results of a small survey of managed care organizations and pharmaceutical manufacturers. J Managed Care Pharm. 2007;13(4):360-371. Does not apply to Economics, Does not apply to health or healthcare.
Nixon J, Khan KS, Kleijnen J. Summarizing economic evaluations in systematic reviews: a new approach. BMJ. 2001;322(7302):1596-8. Article of interest, Methods only, No original analysis. [pmid: 11431306].
Nixon J, Phipps K, Glanville J, et al. Using economic evidence to support decision making: a case study of assertive community treatment within the U.K. national service framework for mental health. Appl Health Econ Health Policy. 2002;1(4):179-190. No original analysis. [pmid: 14619247].
Noyes K, Holloway RG. Evidence from cost-effectiveness research. NeuroRx. 2004;1(3):348-355. Focuses on single condition, Methods only, No original analysis. [pmid: 15717037].
Nuijten MJC, Berto P, Berdeaux G, et al. Trends in decision-making process for pharmaceuticals in western European countries: a focus on emerging hurdles for obtaining reimbursement and a price. Eur J Health Econ. 2001;2(4):162-169. Does not apply to Economics, No original analysis.
Nuijten MJ, Pronk MH, Brorens MJ, et al. Reporting format for economic evaluation. Part II: Focus on modelling studies. Pharmacoeconomics. 1998;14(3):259-68. Costing study, Methods only. [pmid: 10186465].
O'Brien BJ, Heyland D, Richardson WS, et al. Users” guides to the medical literature. XIII. How to use an article on economic analysis of clinical practice. B. What are the results and will they help me in caring for my patients? Evid Based Med.Working Group. JAMA. 197. 277(22):1802-6. No decision making, Methods only, Clinician-level decision making only, Article of interest, Other. [pmid: 9178794].
O'Brien B, Gafni A. When do the “dollars” make sense? Toward a conceptual framework for contingent valuation studies in health care. Med Decis Making. 1996;16(3):288-99. Methods only, No original analysis. [pmid: 8818128].
O'Brien JA, Jacobs LM, Pierce D. Clinical practice guidelines and the cost of care. A growing alliance. Int J Technol Assess Health Care. 2000;16(4):1077-91. No cost effectiveness analysis, No original analysis, Other. [pmid: 11155829].
Ofman JJ, Sullivan SD, Neumann PJ, et al. Examining the value and quality of health economic analyses: implications of utilizing the QHES. J Manag Care Pharm. 2003;9(1):53-61. Article of interest, No original analysis, Not Aim 3 but applies to Aim 2. [pmid: 14613362].
Olchanski N, Slawsky KA, Plent S, et al. Economic impact of switching to bivalirudin for a primary percutaneous coronary intervention in a US hospital. Hosp Pract (Minneap). 2010:138-46. Focused on cost effectiveness of bivalirudin. [pmid: 21068538].
Oliva J, Antonanzas F, Rivero-Arias O. Economic evaluation and decision-making in health. The role of economic evaluation in the adoption and spread of health technologies. 2008 SESPAS Report. Gac Sanit. Suppl 1. 2008;22:137-42. No original analysis. [pmid: 18405563].
Oliva J, Puig-Junoy J, Bernal E. Advances and experiences in economic evaluation of medicines: a complementary view. Gac Sanit. 2008;22(4):358-61. Other. [pmid: 18755088].
Oliver A, Pritchard C. Economic evaluations relating to diabetes: a descriptive review and their compliance with guidance. Value Health. 2000;3(Suppl):17-14. No decision making, No original analysis.
Ollendorf DA, Pearson SD. An integrated evidence rating to frame comparative effectiveness assessments for decision makers. Med Care. 2010:S145-52. Not health care either. [pmid: 20473206].
O'Malley SP, Jordan E. Review of a decision by the Medical Services Advisory Committee based on health technology assessment of an emerging technology: the case for remotely assisted radical prostatectomy. Int J Technol Assess Health Care. 2007;23(2):286-91. No decision making. [pmid: 17493316].
Onukwugha E, Mullins CD, DeLisle S. Using cost-effectiveness analysis to sharpen formulary decision-making: The example of tiotropium at the veterans affairs health care system. Value Health. 2008;11(5):980-988. No decision making. [pmid: 18194405].
Oostenbrink Jan B, Koopmanschap Marc A, Rutten Frans FH. Standardisation of Costs: The Dutch Manual for costing in economic evaluations. Pharmacoeconomics. 2002;20(7):443-454. Costing study, Methods only. [pmid: 12093300].
Otero HJ, Rybicki FJ, Greenberg D, et al. Twenty years of cost-effectiveness analysis in medical imaging: are we improving?. Radiology. 2008;249(3):917-25. No original analysis. [pmid: 19011188].
Pappaioanou M, Malison M, Wilkins K, et al. Strengthening capacity in developing countries for evidence-based public health:The data for decision-making project. Soc Sci Med. 2003;57(10):1925-1937. Article of interest, No original analysis. [pmid: 14499516].
Paisley S. Classification of evidence in decision-analytic models of cost-effectiveness: a content analysis of published reports. Int J Technol Assess Health Care. 2010:458-62. Other. [pmid: 20923588].
Pearson S, Littlejohns P. Reallocating resources: how should the national institute for health and clinical excellence guide disinvestment efforts in the National Health Service?. J Health Serv Res Policy. 2007;12(3):160-165. Methods only, No original analysis, Other. [pmid: 17716419].
Perrier L, Philip T. Contribution of economic evaluation and budget impact analysis to public decision in health: The example of breast cancer. Apports de l'evaluation economique et de l'analyse d'impact budgetaire pour la decision publique en sante: L'exemple du cancer du sein. Bull. Cancer. 2010:397-402. Other. [pmid: 20159674].
Perleth M, Luhmann D, Gibis B, et al. Rapid assessments-quick evaluation of medical technology. Gesundheitswesen. Suppl 1. 2001;63:S79-84. Methods only, No original analysis, Other. [pmid: 11329929].
Persson U. Guidelines for economic evaluation of drugs. Something for Sweden?. Lakartidningen. 1997;94(24):2289-92. Other. [pmid: 9213707].
Phillips CJ, Fordham R, Marsh K, et al. Exploring the role of economics in prioritization in public health: what do stakeholders think?. Eur J Public Health. 2011:578-84. This article is restricted to the views of stakeholders. [pmid: 20817687].
Phillips KA, Chen JL. Impact of the U.S. panel on cost-effectiveness in health and medicine. Am J Prev Med. 2002;22(2):98-105. Article of interest, No original analysis, Other. [pmid: 11818178].
Poppleton VK, Moynihan PJ, Hickey PA. Clinical practice guidelines: The Boston experience. Prog Pediatr Cardiol. 2003;18(1):75-83. Does not apply to Economics.
Porzsolt F, Ackermann M, Amelung V. The value of health care-a matter of discussion in Germany. BMC Health Serv Res. 2007:71. Methods only, No original analysis. [pmid: 17506904].
Postma MJ, Boersma C, Vandijck D, et al. Health technology assessments in personalized medicine: illustrations for cost-effectiveness analysis. Expert Rev Pharmacoecon Outcomes Res. 2011:367-9. Focused on expanding to personalized Medicine at the individual level. [pmid: 21831013].
Postma MJ, Kwik JJ, Rutten WJ, et al. Agreement between guidelines for pharmaco-economic research and never-before-published health-economics evaluations. Ned Tijdschr Geneeskd. 2002;146(23):1082-7. Methods only, No original analysis, Other. [pmid: 12085558].
Price D, Musgrave S, Wilson E, et al. A pragmatic single-blind randomised controlled trial and economic evaluation of the use of leukotriene receptor antagonists in primary care at steps 2 and 3 of the national asthma guidelines (ELEVATE study). Health Technol Assess. 2011:1-132. Other. [pmid: 21554855].
Prosser H, Walley T. A qualitative study of GPs' and PCO stakeholders' views on the importance and influence of cost on prescribing. Soc Sci Med. 2005;60(6):1335-1346. Costing study, Other. [pmid: 15626528].
York Univ. (United Kingdom), NHS Centre for Reviews and Dissemination. Providing reliable evidence to support decision-making: the NHS Economic Evaluation Database (NHS EED). 2002;6(1):4. No decision making, No original analysis.
Quennell P. Getting a word in edgeways? Patient group participation in the appraisal process of the National Institute for Clinical Excellence. Clin Govern Int J. 2003;8(1):39-45. Article of interest.
Raftery J. Methodological limitations of cost-effectiveness analysis in health care: implications for decision making and service provision. J Eval Clin Pract. 1999;5(4):361-6. Methods only. [pmid: 10579700].
Raftery J. NICE faster access to modern treatments? Analysis of guidance on health technologies. BMJ. 2001;323(7324):1300-3. No original analysis. [pmid: 11731399].
Ramsberg J, Odeberg S, Engstrom A, et al. Examining the Quality of Health Economic Analyses Submitted to the Pharmaceutical Benefits Board in Sweden: The First Year. Eur J Health Econ. 2004;5(4):351-356. Not Aim 3 but applies to Aim 2. [pmid: 15452738].
Ramsey SD, Wilschut J, Boer R, et al. A decision-analytic evaluation of the cost-effectiveness of family history-based colorectal cancer screening programs. Am J Gastroenterol. 2010:1861-9. Other. [pmid: 20461066].
Ramsey S, Willke R, Briggs A, et al. Good Research Practices for Cost-Effectiveness Analysis Alongside Clinical Trials: the Ispor Rct-Cea Task Force Report. Value Health. 2005;8(5):521-533. Article of interest, No decision making. [pmid: 16176491].
Rauner MS, Brandeau ML. AIDS policy modeling for the 21st century: an overview of key issues. Health Care Manag Sci. 2001;4(3):165-80. Methods only, No decision making, No original analysis. [pmid: 11519843].
Rawlins MD, Culyer AJ. National Institute for Clinical Excellence and its value judgements. BMJ. 2004;329(7459):224-227. Article of interest, No original analysis, Other. [pmid: 15271836].
Reinhardt UE. Making economic evaluations respectable. Soc Sci Med. 1997;45(4):555-62. No original analysis. [pmid: 9226781].
Report from the Canadian Coordinating Office for Health Technology Assessment (CCOHTA). Guidelines for economic evaluation of pharmaceuticals: Canada. Int J Technol. Assess Health Care. 1995;11(4):796-7. No original analysis. [pmid: 8567213].
Richardson J, Mckie J. Economic Evaluation of Services for a National Health Scheme: the Case for a Fairness-Based Framework. J Health Econ. 2007;26(4):785-799l. Methods only. [pmid: 17328979].
Richter A, Hicks KA, Earnshaw SR, et al. Allocating HIV prevention resources: A tool for state and local decision making. Health Policy. 2008;87(3):342-349. Methods only. [pmid: 18342388].
Rizzo Ilde. The Public Decision-Making Process and Cost-Benefit Analysis. Efficiency in the public sector: The theory and practice of cost-benefit analysis. Williams A, Giardina E, editors. U.K. Aldershot. 1993:158-170. Methods only, No cost effectiveness analysis, No original analysis.
Rizzo JD, Powe NR. Methodological hurdles in conducting pharmacoeconomic analyses. Pharmacoeconomics. 1999;15(4):339-355. Methods only, No original analysis. [pmid: 10537953].
Robinson R. Economic evaluation and health care: what does it mean? First in a series. BMJ. 1993;307(6905):670-673. Methods only, No original analysis. [pmid: 8401057].
Rodriguez-Cobo I, Chen YF, Olowokure B, et al. Clinical and economic assessment of different general population strategies of pertussis vaccine booster regarding number of doses and age of application for reducing whooping cough disease burden: A systematic review. Vaccine. 2008;26(52):6768-76. No original analysis. [pmid: 18835414].
Rodriguez-Monguio R, Antonanzas Villar F. Healthcare rationing in Spain: framework, descriptive analysis and consequences. Pharmacoeconomics. 2006;24(6):537-48. No cost effectiveness analysis, No original analysis. [pmid: 16761902].
Rogowski WH, Landauer M, John J. Decision-analytical modelling of costs per QALY in the context of the German social law. Entscheidungsanalytische Modellierung von Kosten pro QALY im Kontext des deutschen Sozialrechts. Gesundheitswesen. 2009:739-750. Other. [pmid: 19551622].
Rogowski WH, Hartz SC, John JH. Clearing up the hazy road from bench to bedside: a framework for integrating the fourth hurdle into translational medicine. BMC Health Serv Res. 2008:8194. Article of interest, No original analysis.
Rorvik EM, Toverud EL, Walloe L. The introduction of pharmacoeconomic analysis in Norway--are the users prepared?. Pharm World Sci. 2001;23(4):135-44. Limited case study, No original analysis, Other. [pmid: 11599199].
Rosenthal MB, Landon BE, Howitt K, et al. Climbing up the pay-for-performance learning curve: where are the early adopters now?. Health Affairs. 2007;26(6):1674-1682. No cost effectiveness analysis, No decision making. [pmid: 17978386].
Rovira J, Antonanzas F. Economic analysis of health technologies and programmes. A Spanish proposal for methodological standardisation. Pharmacoeconomics. 1995;8(3):245-52. No original analysis. [pmid: 10155620].
Rovira J. Economic evaluation in health: From research to decision making. evaluacion economica en salud: de la investigacion a la toma de decisiones. Rev Esp Salud Publica. 2004;78(3):293-295. Other. [pmid: 15293952].
Rovira-Forns J, Antonanzas-Villar F. Economic evaluation studies in health. Med Clin (Barc). Suppl 1. 2005;125:61-7. No decision making, No original analysis, Other. [pmid: 16464430].
Rovithis D. Health economic evaluation in Greece. Int J Technol Assess Health Care. 2006;22(3):388-95. Limited case study, No decision making, No original analysis, Other. [pmid: 16984068].
Ruckdaschel S, Reiher M, Rohrbacher R, et al. The role of health economics in telemedicine. Dis Manag Health Outcome. 2006:143-7. No decision making.
Russell LB, Fryback DG, Sonnenberg FA. Is the societal perspective in cost-effectiveness analysis useful for decision makers?. Jt Comm J Qual Improv. 1999;25(9):447-454. No original analysis. [pmid: 10481813].
Rutten F. Economic evaluation and health care decision-making. Health Policy. 1996;36(3):215-29. No original analysis. [pmid: 10158267].
Saez CA, Requena JC. Reconciling sustainability and discounting in cost-benefit analysis: a methodological proposal. Ecol Econ. 2007;60(4):712-725. Does not apply to health or healthcare.
Saint S, Veenstra DL, Sullivan SD. The use of meta-analysis in cost-effectiveness analysis. Issues and recommendations. Pharmacoeconomics. 1999;15(1):1-8. No decision making. [pmid: 10345156].
Saleh KJ, Gafni A, Macaulay WB, et al. Understanding economic evaluations: a review of the knee arthroplasty literature. Am J Knee Surg. 1999;12(3):155-60. No decision making, No original analysis. [pmid: 10496464].
Salzer MS. United States mental health policy in the 1990s: an era of cost-effectiveness, research and consumerism. Policy Polit. 1999;27(1):75-84. Limited case study, No original analysis.
Sanchez Martinez FI, Abellan Perpinan JM, et al. How should health and healthcare priorities be set and evaluated? Prioritization methods and regional disparities. 2008 SESPAS Report. Gac Sanit. Suppl 1. 2008;22:126-36. No original analysis. [pmid: 18405562].
Sancho LG, Vargens JM. Health economic evaluation in a local level government health care system. Cien Saude Colet. 2009:1513-21. No ACTUAL use of EE for decision making. [pmid: 19750361].
Sassi F, Le Grand J, Archard L. Equity versus efficiency: a dilemma for the NHS: if the NHS is serious about equity it must offer guidance when principles conflict. BMJ. 2001;323(7316):762-763. No original analysis. [pmid: 11588063].
Savage AM. A study of economic evaluation methods and their contribution to knowledge in the field of urinary incontinence. Journal of the Association of Chartered Physiotherapists in Women's Health. 2004;(94):42-53. No decision making.
Schackman BR, Gold HT, Stone PW, et al. Do differences among cost-effectiveness analysis guideline recommendations affect policy conclusions?. Value Health. 2003;6(3):296-297. Methods only, No original analysis.
Schauffler HH, Parkinson MD. Health insurance coverage for smoking cessation services. Health Educ Q. 1993;20(2):185-206. No cost effectiveness analysis, No original analysis. [pmid: 8491632].
Schlander M. The NICE ADHD health technology assessment: A review and critique. Child Adolesc Psychiatry Ment Health. 2008:2. No original analysis, No decision making, No original analysis. [pmid: 18226213].
Schulenburg Jmgvd, Vauth C, Mittendorf T, et al. Methods for determining cost-benefit ratios for pharmaceuticals in Germany. Eur J Health Econ. 2007;8:S5-S31. Methods only. [pmid: 17582539].
Schwappach DLB. Are preferences for equality a matter of perspective?. Med Decis Making. 2005;25(4):449-459. Does not apply to Economics. [pmid: 16061897].
Schwappach DL, Boluarte TA. HEE-GER: a systematic review of German economic evaluations of health care published 1990-2004. BMC Health Serv Res. 2007:77. Methods only, No original analysis, Other. [pmid: 17540025].
Scott A, Shiell A, King M. Is general practitioner decision making associated with patient socio-economic status?. Soc Sci Med. 1996;42(1):35-46. No cost effectiveness analysis, No original analysis, Other. [pmid: 8745106].
Sculpher M, Claxton K. Sins of omission and obfuscation: IQWIG's guidelines on economic evaluation methods. Health Econ. 2010:1132-6. Other. [pmid: 20662107].
Sculpher MJ, Drummond MF. Analysis Sans Frontieres - can we ever make economic evaluations generalisable across jurisdictions?. Pharmacoeconomics. 2006;24(11):1087-1099. No original analysis. [pmid: 17067194].
Sculpher M. Subgroups and heterogeneity in cost-effectiveness analysis. Pharmacoeconomics. 2008;26(9):799-806. Methods only, No original analysis. [pmid: 18767899].
Severens JL, van der Wilt GJ. Economic evaluation of diagnostic tests. A review of published studies. Int J Technol Assess Health Car. 1999;15(3):480-96. Methods only, No decision making, No original analysis.
Shaw JW. Use of patient versus population preferences in economic evaluations of health care interventions. Clin Ther. 2011:898-900. Editorial only. [pmid: 21715009].
Shani S, Siebzehner MI, Luxenburg O, et al. Setting priorities for the adoption of health technologies on a national level-the Israeli experience. Health Policy. 2000;54(3):169-85. No original analysis. [pmid: 11154787].
Shannon S. Critical appraisal of economic analysis studies. Can Assoc Radiol J. 2002;53(5):251-4. Does not apply to Economics, No original analysis. [pmid: 12500374].
Shapiro L. AMCP eDossier system helps evaluate product value and aids in formulary decision making. Formulary. 2010:179. Other.
Shapiro S. Evaluating the benefits and costs of regulatory reforms: what questions need to be asked?. Eval Program Plann. 2008;31(3):223-30. Costing study, Does not apply to Economics, Does not apply to health or healthcare. [pmid: 18486971].
Shearer JC, Stack ML, Richmond MR, et al. Accelerating policy decisions to adopt haemophilus influenzae type B vaccine: a global, multivariable analysis. PLoS Med. 2010:e1000249. Study does not focus on economic evaluations. [pmid: 20305714].
Sheehan DV, Wright-Etter PJ. Impact of formulary restrictions on the cost-effectiveness of antidepressant treatment. Manag Care Q. 2002;10(3):21-31. Article of interest, No original analysis. [pmid: 12476662].
Shemer J, Abadi-Korek I, Seifan A. Medical technology management: bridging the gap between theory and practice. Isr Med Assoc J. 2005;7(4):211-5. Does not apply to Economics. [pmid: 15847198].
Shemilt I, Mugford M, Drummond M, et al. Economics methods in Cochrane systematic reviews of health promotion and public health related interventions. BMC Med Res Methodol. 2006;6(-):55. Methods only, No original analysis. [pmid: 17107612].
Sherriff R, Best L, Roderick P. Population screening in the NHS: a systematic pathway from evidence to policy formulation. J Public Health Med. 1998;20(1):58-62. Does not apply to Economics, No original analysis. [pmid: 9602450].
Shih STF, Crowley S, Sheu JC. Cost-effectiveness Analysis of a Two-stage Screening Intervention for Hepatocellular Carcinoma in Taiwan. J Formos Med Assoc. 2010:39-55. Other. [pmid: 20123585].
Siegel JE, Goldie SJ. Does cost-effectiveness analysis make a difference? Lessons from pap smears - preface. Med Decis Making. 2001;21(4):307-323. No original analysis. [pmid: 11475387].
Simoens S. Health technology assessment and economic evaluation across jurisdictions. Value in Health. 2010:857-859. NO ACTUAL use of EE in decision making--this is a methods/commentary. [pmid: 20701730].
Single E. New Guidelines for Estimating the Economic Costs of Smoking and Results from Canada. 1999:95-108. Methods only, No cost effectiveness analysis, No decision making.
Sisk JE. How are health care organizations using clinical guidelines?. Health Aff (Millwood). 1998;17(5):91-109. Does not apply to Economics, No cost effectiveness analysis. [pmid: 9769574].
Skaer TL, Sclar DA, Robison LM, et al. The Need for an Iterative Process for Assessing Economic Outcomes Associated With Ssris. Pharmacoeconomics. 2000;18(3):205-214. Methods only, No original analysis. [pmid: 11147388].
Skrepnek GH. The contrast and convergence of bayesian and frequentist statistical approaches in pharmacoeconomic analysis. Pharmacoeconomics. 2007;25(8):649-664. Does not apply to Economics, No original analysis. [pmid: 17640107].
Sloan FA, Whetten-Goldstein K, Wilson A. Hospital pharmacy decisions, cost containment, and the use of cost-effectiveness analysis. Soc Sci Med. 1997;45(4):523-533. Costing study, Other. [pmid: 9226778].
Sloan FA, Conover CJ. The use of cost-effectiveness/cost-benefit analysis in actual decision making: Current Status and Prospects. 1995:207-232. Methods only, No decision making, No original analysis.
Selby Smith C. From research to action: does economic evaluation affect health policy or practice?. Proceedings of the Fifteenth Australian Conference of Health Economist. 1994:225-243. No original analysis.
Soares M, Dumville JC. Economic evaluation of healthcare technologies using primary research. Evid Based Nurs. 2008;11(3):67-71. Focuses on single condition, Methods only, No original analysis. [pmid: 18583483].
Sonnenberg FA, Roberts MS, Tsevat J, et al. Toward a peer-review process for medical decision-analysis models. Med Care. 1994;32(7):JS52-JS64. Does not apply to Economics, No original analysis. [pmid: 8028413].
Soucat A, Levy-Bruhl D, Gbedonou P, et al. Local cost sharing in Bamako Initiative systems in Benin and Guinea: assuring the financial viability of primary health care. Int J Health Plann Manage. Suppl 1. 1997;12:S109-35. Costing study, Other. [pmid: 10169906].
Soumerai SB, Ross-Degnan D, Fortess EE, et al. Determinants of change in Medicaid pharmaceutical cost sharing: does evidence affect policy?. Milbank Q. 1997;75(1):11-34. Cost predictors only, Costing study, No cost effectiveness analysis. [pmid: 9063299].
Spath HM, Carrere MO, Fervers B, et al. Analysis of the eligibility of published economic evaluations for transfer to a given health care system.Methodological approach and application to the French health care system. Health Policy. 1999;49(3):161-77. Methods only. [pmid: 10827295].
Spoorendonk PAR. Panacea or new hurdle? Pharmacoeconomic evaluation in the Netherlands. spoorendonk par, panacee of niewe horde? Farmaco-economische toetsing in nederland. Pharm Weekbl. 2001;136(19):674-679. No original analysis, Other.
Sroczynski G, Schnell-Inderst P, Muhlberger N, et al. Cost-effectiveness of primary HPV screening for cervical cancer in Germany-a decision analysis. Eur J Cancer. 2011:1633-46. Other. [pmid: 21482103].
Stafinski T, Menon D, McCabe C, et al. To fund or not to fund development of a decision-making framework for the coverage of new health technologies. Pharmacoeconomics. 2011:771-780. Other. [pmid: 21756008].
Stallen P, Jan-van HW, et al. Summary of the issues discussed. Quantified societal risk and policy making. Springer. 1998:212-229. Does not apply to Economics, No original analysis.
Stein K, Fry A, Round A, et al. What value health? A review of health state values used in early technology assessments for NICE. Appl Health Econ Health Policy. 2005;4(4):219-28. No cost effectiveness analysis, No original analysis. [pmid: 16466273].
Steuten L, Vrijhoef B, Severens H, et al. Are we measuring what matters in health technology assessment of disease management? Systematic literature review. Int J Technol Assess Health Care. 2006;22(1):47-57. Does not apply to Economics, No original analysis. [pmid: 16673680].
Stevens A, Milne R, Burls A. Health technology assessment: history and demand. J Public Health. 2003;25(2):98-101. Article of interest, does not apply to Economics, No original analysis.
Stewart A, Schmier JK, Luce BR. Economics and cost-effectiveness in evaluating the value of cardiovascular therapies. A survey of standards and guidelines for cost-effectiveness analysis in health care. Am Heart J. 1999;137(5):S53-61. No original analysis. [pmid: 10220598].
Stiggelbout AM, De Vogel-Voogt E. Health state utilities: A framework for studying the gap between the imagined and the real. Value Health. 2008;11(1):76-87. Methods only, No original analysis. [pmid: 18237362].
Stille C, Turchi RM, Antonelli R, et al. The family-centered medical home: specific considerations for child health research and policy. Acad Pediatr. 2010:211-217. Other. [pmid: 20605546].
Stolk EA, Brouwer WB, Busschbach JJ. Rationalizing rationing: economic and other considerations in the debate about funding of Viagra. Health Policy. 2002;59(1):53-63. No original analysis. [pmid: 11786174].
Suh DC, Okpara IR, Agnese WB, et al. Application of Pharmacoeconomics to formulary decision making in managed care organizations. Am J Manag Care. 2002;8(2):161-9. No original analysis. [pmid: 11858228].
Sundmacher T, Jasper J. Ausgestaltungsvarianten und okonomische Konsequenzen einer 4. Hurde fur die Erstattung von Arzneimitteln. (With English summary.). Zeitschrift fur Wirtschaftspolitik. 2006;55(1):92-124. No original analysis, Other.
Sutton AJ, Cooper NJ, Goodacre S, et al. Integration of meta-analysis and economic decision modeling for evaluating diagnostic tests. Med Decis Making. 2008;28(5):650-667. Methods only. [pmid: 18753686].
Sweet B, Tadlock CG, Waugh, et al. The WellPoint Outcomes Based Formulary: enhancing the health technology assessment process. Journal of Drug Assessment. 2005;8(1):45-57. Limited case study.
Tabuteau D. Decision-making in health. Sante Publique. 2008;20(4):297-312. No original analysis. [pmid: 19014082].
Tan EL, Day RO, Brien JA. Perspectives on drug and therapeutics committee policy implementation. Res Social Adm Pharm. 2005;1(4):526-45. No cost effectiveness analysis, Other. [pmid: 17138494].
Tang A, Penman A. The role of economic analysis in policy making-a tobacco control case study. NSW Public Health Bull. 2005;16(11-12):201-3. No decision making, No original analysis.
Tappenden P, Brennan A, Chilcott J, et al. Using whole disease modelling to inform economic recommendations for the detection, diagnosis, treatment and follow-up of colorectal cancer. Value Health. 2011:A469-A470. No abstractable data.
Tavakoli M, Davies HTO, Malek M, et al. 2001. Health: Government Policy; Regulation; Public Health I180. No original analysis, Other.
Taylor RS, Drummond MF, Salkeld G, et al. Inclusion of cost effectiveness in licensing requirements of new drugs: the fourth hurdle. BMJ. 2004;329(7472):972-975. No original analysis. [pmid: 15499118].
Teerawattananon Y, Russell S, Mugford M. A systematic review of economic evaluation literature in Thailand: are the data good enough to be used by policy-makers?. Pharmacoeconomics. 2007;25(6):467-79. No original analysis, Other. [pmid: 17523752].
Tilson L, O'Leary A, Usher C, et al. Pharmacoeconomic evaluation in Ireland: a review of the process. Pharmacoeconomics. 2010:307-22. Focuses on pharmacy issues only. [pmid: 20222754].
Tohda Y, Nishima S, Arakawa I, et al. Cost-effectiveness of salmeterol/fluticasone combination therapy vs. fluticasone propionate in Japanese asthmatic patients. Yakugaku Zasshi. 2010:593-603. also not in English. [pmid: 20372007].
Tu HAT, Woerdenbag HJ, Kane S, et al. Economic evaluations of hepatitis B vaccination for developing countries. Expert Rev Vaccines. 2009:907-920. Other. [pmid: 19538116].
American Society on Aging. The 10% solution. Aging Today. 2005;26(4):9. Costing study, No original analysis.
The OECD Health Project. Health Technologies and Decision Making. Paris and Washington, D.C. 2005. No original analysis, Other.
Timmins N. Bills, bills, bills: problems for NICE. BJHCM. 2008;14(9):374-375. No original analysis, Other.
Tobin CT. Economic issues of diabetes care and management. Diabetes Spectrum. 1995;8(3):144-168. No original analysis.
Torti FM, Reed SD, Schulman KA. Analytic considerations in economic evaluations of multinational cardiovascular clinical trials. Value Health. 2006;9(5):281-91. Methods only, No decision making, No original analysis, Other. [pmid: 16961546].
Townsend J, Buxton M, Harper G. Prioritization of health technology assessment. The PATHS model: methods and case studies. Health Technol Assess. 1. 2003;7(20):iii-82. Does not apply to Economics.
Tracy M, Kruk ME, Harper C, et al. Neo-liberal economic practices and population health: a cross-national analysis,1980-2004. Health Econ Policy Law. 2010:171-99. Commentary. [pmid: 19723354].
Treloar CJ, Hewitson PJ, Henderson KM, et al. Factors influencing the uptake of technologies to minimize perioperative allogeneic blood transfusion: An interview study of national and institutional stakeholders. Intern Med J. 2001;31(4):230-236. Does not apply to Economics. [pmid: 11456036].
Trosman JR, Van Bebber SL, Phillips KA. Health technology assessment and private payers' coverage of personalized medicine. J Oncol Pract. 2011:18s-24s. Focus is not on cost effectiveness but health technology assessments in private payer decisions. [pmid: 21886515].
Trueman P, Drummond M, Hutton J. Developing guidance for budget impact analysis. Pharmacoeconomics. 2001;19(6):609-621. Not Aim 3 but applies to Aim 2. [pmid: 11456210].
Tunis SR, Pearson SD. US moves to improve health decisions. BMJ. 2010:c3615. Other. [pmid: 20732966].
Tu HA, Woerdenbag HJ, Kane S, et al. Economic evaluations of rotavirus immunization for developing countries: a review of the literature. Expert Rev Vaccines. 2011:1037-51. Mentions decision making but doesn't discuss impact only impact of cost. [pmid: 21806398].
Udvarhelyi IS, Colditz GA, Rai A, et al. Cost-effectiveness and cost-benefit analyses in the medical literature. Are the methods being used correctly?. Ann Intern. 1992;116(3):238-44. Methods only.
Urdahl H, Manca A, Sculpher MJ. Assessing generalisability in model-based economic evaluation studies - a structured review in osteoporosis. Pharmacoeconomics. 2006;24(12):1181-1197. Methods only, No original analysis. [pmid: 17129074].
U'Ren NA. Using pharmaceutical cost analyses for decision making. Hosp Cost Manag Accoun. 1997;9(8):1-7. Costing study.
Urquhart B, Mitton C, Peacock S. Introducing priority setting and resource allocation in home and community care programs. J Health Serv Res Policy. Suppl 1. 2008;13:41-5. Focuses on single condition, Limited case study. [pmid: 18325168].
Vallejo-Torres L, Steuten LM, Buxton MJ, et al. Integrating health economics modeling in the product development cycle of medical devices: a Bayesian approach. Int J Technol Assess Health Care. 2008;24(4):459-64. Methods only. [pmid: 18828941].
Van-den, Oever R. Cost-effectiveness in surgery. The insurers' point of view. Acta Chir Belg. 1995;95(5):205-210. No original analysis. [pmid: 7502616].
Van-der-Velde G, Cote P, Bayoumi AM, et al. Protocol for an economic evaluation alongside the University Health Network Whiplash Intervention Trial: cost-effectiveness of education and activation, a rehabilitation program, and the legislated standard of care for acute whiplash injury in Ontario. BMC Public Health. 2011:594. This paper describes the protocol only. [pmid: 21794155].
Van-Gestel A, Grutters J, Schouten J, et al. The role of the expected value of individualized care in cost-effectiveness analyses and decision making. Value Health. 2012:13-21. Other. [pmid: 22264967].
Van-Velden, Marieke E, Severens JL, et al. Economic evaluations of healthcare programmes and decision making: the influence of economic evaluations on different healthcare decision-making levels. Pharmacoeconomics. 2005;23(11):1075-1082. No original analysis. [pmid: 16277545].
Vallejo-Torres L, Steuten L, Parkinson B, et al. Integrating health economics into the product development cycle: a case study of absorbable pins for treating hallux valgus. Med Decis Making. 2011:596-610. Specific to a single disease of condition. [pmid: 21127320].
Vanni T, Luz PM, Ribeiro RA, et al. Economic evaluation in health: applications in infectious diseases. Cad Saude Publica. 2009:2543-52. Other. [pmid: 20191146].
Veenstra DL, Higashi MK, Phillips KA. Assessing the cost-effectiveness of pharmacogenomics. Aaps Pharmsci. 2000;2(3). art. no.-29. Methods only, No original analysis.
Vegter S, Rozenbaum MH, Postema R, et al. Review of regulatory recommendations for orphan drug submissions in the Netherlands and Scotland: focus on the underlying pharmacoeconomic evaluations. Clin Ther. 2010:1651-61. [pmid: 20974323].
Vegter S, Jansen E, Postma MJ, et al. Economic evaluations of pharmacogenetic and genomic screening programs: Update of the literature. Drug Dev Res. 2010:492-501. Review and no decision making component.
Vinck I, Neyt M, Thiry N, et al. Introduction of emerging medical devices on the market: a new procedure in Belgium. Int J Technol Assess Health Care. 2007;23(4):449-54. Methods only, No original analysis. [pmid: 17937833].
Viney R. Funding arrangements for pharmaceuticals: can economic evaluation promote efficiency?. Aust Health Rev. 2001;24(2):21-24. No original analysis. [pmid: 11496466].
Von-Der, Schulenburg JMG, Vauth C. According to which economic methods should health care services become evaluated in Germany?. Jahrb Natl Okon Stat. 2007;227(5-6):787-805. Not Aim 3 but applies to Aim 2.
Vuorenkoski L, Toiviainen H, Hemminki E. Decision-making in priority setting for medicines - a review of empirical studies. Health Policy. 2008;86(1):1-9. No original analysis. [pmid: 17950484].
Wahlqvist ML, Lee MS, Lau J, et al. The opportunities and challenges of evidence-based nutrition (EBN) in the Asia Pacific region: clinical practice and policy-setting. Asia Pac J Clin Nutr. 2008;17(1):2-7. Does not apply to Economics, No original analysis. [pmid: 18364319].
Walker D. Cost and cost-effectiveness guidelines: which ones to use?. Health Policy Plan. 2001;16(1):113-21. No original analysis. [pmid: 11238438].
Walkom E, Robertson J, Newby D, et al. The role of pharmacoeconomics in formulary decision-making - considerations for hospital and managed care pharmacy and therapeutics committees. Formulary. 2006;41(8):374. Article of interest, No original analysis.
Wathen B, Dean T. An evaluation of the impact of NICE guidance on GP prescribing. Br J Gen Pract. 2004;54(499):103-7. No decision making. [pmid: 14965388].
Weatherly H, Drummond M, Claxton K, et al. Methods for assessing the cost-effectiveness of public health interventions: key challenges and recommendations. Health Policy. 2009:85-92. Other. [pmid: 19709773].
Weinstein MC, O'Brien B, Hornberger J, et al. Principles of good practice for decision analytic modeling in health-care evaluation: report of the ISPOR Task Force on Good Research Practices--Modeling Studies. Value Health. 2003;6(1):9-17. Does not apply to Economics, Methods only. [pmid: 12535234].
Welte R, Trotter C, Edmunds J, et al. Economic evaluation of Meningococcal C vaccination programmes and its impact on decision making. Value Health. 2004;7(6):767. No original analysis.
Wenstop F, Magnus P. Value focused rationality in AIDS policy. Health Policy. 2001;57(1):57-72. No cost effectiveness analysis, No original analysis. [pmid: 11348694].
Whiting JF. Standards for economic and quality of life studies in transplantation. Transplantation. 2000;70(7):1115-21. Not Aim 3 but applies to Aim 2. [pmid: 11045656].
Whitten P, Kuwahara E. Telemedicine from the payor perspective - considerations for reimbursement decisions. Dis Manag Health Outcome. 2003;11(5):291-298. No original analysis.
Willan AR. Clinical decision making and the expected value of information. Clin Trials. 2007;4(3):279-285. No decision making. [pmid: 17715257].
Williams IP, Bryan S. Cost-effectiveness analysis and formulary decision making in England: Findings from research. Soc Sci Med. 2007;65(10):2116-2129. Does not apply to Economics, Methods only. [pmid: 17698271].
Williams IP, Bryan S. Cost-effectiveness analysis and formulary decision making in England: Findings from research. Soc Sci Med. 2007;65(10):2116-2129. No cost effectiveness analysis. [pmid: 17698271].
Windmeijer F, Kontodimas S, Knapp M, et al. Methodological approach for assessing the cost-effectiveness of treatments using longitudinal observational data: the SOHO study. Int J Technol Assess Health Care. 2006;22(4):460-8. Focuses on single condition, Methods only, No decision making. [pmid: 16984679].
Winkens R, Dinant G. Education and debate Evidence base of diagnostic research: rational, cost effective use of investigations in clinical practice,last in a series of five articles. BMJ. 2002;324(7340):783-785. No original analysis. [pmid: 11924663].
Wonder MJ, Neville AM, Parsons R. Are Australians able to access new medicines on the pharmaceutical benefits scheme in a more or less timely manner? An analysis of pharmaceutical benefits advisory committee recommendations, 1999-2003. Value Health. 2006;9(4):205-212. Does not apply to Economics, Other. [pmid: 16903989].
Wonderling D, Sawyer L, Fenu E, et al. National clinical guideline centre cost-effectiveness assessment for the national institute for health and clinical excellence. Ann Intern Med. 2011:758-765. Methods and this is not an original checklist. [pmid: 21646559].
Wong PK. Evidence-based practice to evidence-based policy: do we really impact on patient care?. Value Health. 2005;8(4):451-452. Limited case study, No original analysis. [pmid: 16091021].
Wyman M, Feeley J, Brimacombe G, et al. Core and comprehensive health care services: 4. Economic issues. CMAJ. 1995;152(10):1601-4. No cost effectiveness analysis, No original analysis. [pmid: 7743446].
Yang BM, Bae EY, Kim J. Economic evaluation and pharmaceutical reimbursement reform in South Korea's National Health Insurance. Health Affairs. 2008;27(1):179-187. No original analysis. [pmid: 18180493].
Yamauchi H, Nakagawa C, Yamashige S, et al. Decision impact and economic evaluation of the 21-gene recurrence score (RS) assay for physicians and patients in Japan. Eur J Cancer. 2011:S378. Decision making level is individual. [pmid: 21944022].
Yang M, Rajan S, Issa AM. A cost-effectiveness analysis of two commercially available gene expression profiling tests: Implications for reimbursement decision-making and policy. J Popul ther Clin Pharmacol. 2011:e188-e189. Other.
Yee GC, Hillman AL. Applied Pharmacoeconomics. When can publication be legitimately withheld?. Pharmacoeconomics. 1997;12(5):511-6. No original analysis, Other. [pmid: 10174317].
Yokl RT. Back talk. Value analytics: the new science of saving: process offers better information, decision making and control. HPN Hosp Purch News. 2009:52. Other.
Yothasamut J, Tantivess S, Teerawattananon Y. Using economic evaluation in policy decision-making in Asian countries: mission impossible or mission probable?. Value Health. 2009:S26-30. Other. [pmid: 20586976].
Zarate V, Kind P, Chuang LH. Hispanic Valuation of the EQ-5D Health States: A social value set for Latin Americans. Value Health. 2008. No cost effectiveness analysis.
Zavala SK, French MT, Henderson CE, et al. Guidelines and challenges for estimating the economic costs and benefits of adolescent substance abuse treatments. J Subst Abuse Treat. 2005;29(3):191-205. Limited case study, No decision making, No original analysis. [pmid: 16183468].
Zwerling C, Daltroy LH, Fine LJ, et al. Design and conduct of occupational injury intervention studies: a review of evaluation strategies. Am J Ind Med. 1997;32(2):164-79. Does not apply to Economics, No cost effectiveness analysis, No original analysis. [pmid: 9215438].