# Study Quality Form

This is the study quality form. It asks several questions under each of these topic areas: JADAD (quality of controlled trials), survey, qualitative research, and observational/qualitative/structured interviews.