# Data Abstraction Form

This is the data abstraction form. For each study, it collects information on the study's applicability to aim 3 using 11 questions, and it asks participants to identify promoting factors and/or barries of the policy study outcomes and provide supporting evidence.