# Article Inclusion/Exclusion Forms

These are the article inclusion/exclusion forms. They ask which aim the article applies to and ask participants to fill out several checklists, including a list of reasons the study does not apply to the aims, the level of study detail, whether external examination or feedback was provided, the type of data collection, the type of case studies, the level of policy, and the reasons for exclusion. The forms also provide comment sections.