# Abstract Review Form

This is the abstract review form. For each abstract, it asks one question about whether the article potentially applies to Aim 2 or Aim 3. The form also asks participants to indicate which of the reasons listed that the abstract does not apply, and asks participants to indicate whether it cannot be determined or whether the abstract was unavailable.