# Title Review Form^*^ * Screening forms and data abstraction forms appearing in appendices B-F were recreated using Distiller SR for the purposes of illustration

This is the title review form. For each title, it asks one question about whether the article potentially applies to Aim 2 or Aim 3. Aim 2 is systems that have been used to evaluate best practices for conducting economic evaluations in health care. Aim 3 is studies addressing the issues of using economic outcomes in policy and decisionmaking.