# Search Strategies

Search strategies

Database | Search | | | Results
PubMed | A | B | C
PubMed | “Cost –benefit analysis”[mh] “Cost of illness”[mh] “economic evaluation”[tiab] “economic outcomes”[tiab] (analysis[tiab] AND (cost[tiab] OR economic[tiab])) “cost effectiveness”[tiab] | “decision making”[mh] “Health Policy”[Mesh] “Decision Making”[tiab] reimbursement[tiab] “Evidence-Based Medicine”[mh] “Evidence-Based Medicine”[tiab] “Technology Assessment, Biomedical”[mh] “Technology Assessment”[tiab] formularies[mh] guideline*[tiab] recommend*[tiab] | Evaluations[tiab] “evaluation”[tiab] “qualitative”[tiab] “focus group”[tiab] Interview[tiab] observation[tiab] outcomes[tiab] analysis[tiab] analyses[tiab]
PubMed | A and B and C (limited 1991 to present) | | | 12219
EconLit and Cumulative Index to Nursing and Allied Health Literature (CINAHL) | A | B | C
EconLit and Cumulative Index to Nursing and Allied Health Literature (CINAHL) | TX “cost-benefit analysis” TX “cost of illness” TX “economic evaluation” TX “economic outcomes” TX “cost effectiveness” TX “cost analysis” TX “economic analysis” | TX “Decision making” TX “health policy” TX reimbursement TX “evidence-based medicine” TX “Technology assessment” TX formulary TX guideline | TX evaluation TX qualitative TX “focus group” TX interview TX observation TX outcome TX analysis
EconLit and Cumulative Index to Nursing and Allied Health Literature (CINAHL) | A and B and C (limited 1991 to present) | | | 5555
Embase | A | B | C
Embase | ‘cost of illness’:ti,ab ‘cost benefit analysis’:ti,ab ‘economic evaluation’:ti,ab ‘economic outcomes’:ti,ab (‘analysis’:ti,ab AND (‘cost’:ti,ab OR economic:ti,ab)) ‘cost effectiveness’:ti,ab AND [humans]/lim | ‘decision making’:ti,ab ‘health care policy’:ti,ab ‘evidence based medicine’:ti,ab formulary:ti,ab reimbursement:ti,ab ‘technology assessment’:ti,ab guideline:ti,ab AND [humans]/lim | evaluation:ti,ab evaluations:ti,ab qualitative:ti,ab ‘focus group’:ti,ab interview:ti,ab observation:ti,ab outcome:ti,ab analysis:ti,ab AND [humans]/lim
Embase | A and B and C (limited 1991 to present) | | | 3296
ISI Web of Science | A | B | C
ISI Web of Science | TS=(“cost benefit analysis” OR “cost of illness” OR “economic evaluation” OR “economic outcome” OR “cost effectiveness”) | TS=(“decision making” OR “health policy” OR “reimbursement” OR “evidence based medicine” OR “technology assessment” OR “formulary” OR “guideline” OR “recommendation”) | TS=(evaluation OR qualitative OR “focus group” OR interview OR observation OR outcomes OR analysis)
ISI Web of Science | A and B and C (limited 1991 to present) | | | 3881
| TOTAL | | | 24984
| overlap between databases | | | 5857
| Reviewed total | | | 19127