# Suggested Framework for Deciding When a Modeling Effort Should be Added to a Systematic Review

## Overview

This chapter provides a framework for deciding when a decision analysis should be conducted in addition to a systematic review. While the goal of a systematic review is to synthesize the current scientific literature on a particular topic to assist decisionmakers, there are often limitations with the evidence available to fully address the questions that are most relevant for decisionmakers. Decision-analytic models can be used to simulate the health outcomes of individual patients or populations under a variety of scenarios and they represent the core methodology of clinical decision analysis. Models may provide added value alongside systematic reviews by adding a formal structure, which can be informed by the evidence. We present several situations that would be appropriate to consider including a decision modeling project, and discuss the role of the stakeholder(s) within the framework. We also discuss issues pertaining to who would conduct the modeling studies, the timing of such studies, and the evaluation of existing models.

## Proposed Framework

To help inform a framework to decide when a decision model should be added to a systematic review, we conducted key informant interviews with: (1) members from all of the Evidence-based Practice Centers (EPCs), (2) members of the United States Preventive Services Task Force (USPSTF), and (3) cancer modelers involved with recent modeling work with the USPSTF. Overall, we found strong support for establishing guidance for the use of models as an adjunct to systematic reviews. To that end, we address the many themes and concerns that arose during those interviews and make specific recommendations to consider. Details from the interviews are provided in other chapters, and a list of the types of systematic reviews is in Appendix E.

### Scope

There was some discussion during the interviews about the distinction between using models within (as part of) a systematic review versus using a model alongside (as a separate project) a systematic review. Concerns about including models within a systematic review ranged from the fact that modeling is beyond the scope and “spirit” of an evidence review, and that it would add greatly to the time and resources (and skill set) required to complete the systematic review. Decision modeling can be viewed as a separate endeavor, but one that is fully integrated with the systematic review effort. This designation allows for an appropriate distinction between the “spirit” of modeling and evidence reviews. While the goal of a systematic review is to synthesize and grade all of the available evidence, the goal of a decision model is to provide a tool to the decisionmaker that projects relevant health outcomes for all of the available options for several population subgroups. A decision model should incorporate all of the available evidence (i.e., results from a systematic review) but is not limited to that evidence base. For example, a model can be used to extend the findings from a systematic review by addressing gaps in the literature, extending benefits and harms beyond intermediate outcomes (e.g., cancer incidence) to terminal outcomes (e.g., death from cancer), and offering comparisons of strategies that were not directly compared in the literature. The decision modeling endeavor should also be integrated with the stakeholder and the systematic review team. This would ensure that the decision model is informed by the best available evidence and is relevant to the decisionmaker.

### Engagement by the Stakeholder

We start with the premise that systematic reviews are conducted to assist stakeholders with decisionmaking. A model developed by a technical team, that was not informed by any interactions between the team and the decisionmaker, will not be successful no matter how sophisticated or well done the decision model is. Thus, the engagement of the stakeholder early in the question development and/or refinement phase is critical. If the stakeholder's goals are focused solely on the state of the evidence for the particular topic then there would be minimal value to including a modeling study. One exception to this might be using a model to conduct a formal value of information analysis, where a model can be used to quantify the value of conducting further research. If the goals of the stakeholder are to inform decisions; whether it is guideline development, coverage decisions, or other types of recommendations; then there should be consideration given to incorporating a modeling component.

Another important discussion to have during the question refinement stage addresses the distinction between two philosophically different approaches to decisionmaking. The first values empiricism with a hierarchy of acceptable “evidence,” while the second values using “best available data” and utilizing, cautiously, expert opinion as well as poorer quality of evidence in models designed to inform decisions. In other words, is it acceptable for the decisionmaker to make decisions on the basis of a model that includes both good and poor quality data with clinically reasonable assumptions made when necessary to fill in evidence gaps? Stakeholders need to understand and weigh in on their decisionmaking philosophy, and understand the implications of moving forward with a modeling component.

The first step in the process should be to engage the stakeholder in discussions about the goals of decision modeling and how it could potentially add value to the topic being addressed (though there may be timing issues discussed below). This will likely require that the stakeholder be educated on what a decision model is, how they have been used in practice, and what their value is in this context. For example, for the modeling work done for the USPSTF, a “Decision Models 101” presentation was developed and presented to USPSTF members as a tutorial, in preparation for the discussion of results. This was viewed by several USPSTF members as an excellent session during our interviews. Because the goal of using a decision model is to assist the decisionmaker, it is important for the decisionmaker to be “on board” at the start and be willing to be engaged in the process. Ultimately, the success of using a decision model should be reflected in its value to the decisionmaker.

### When Would a Modeling Study Be Helpful?

Of course to determine a priori when a modeling study would be helpful is a challenge. A modeling study would almost always be helpful, in that it provides decisionmakers with a logical and transparent framework for thinking about the tradeoffs between harms and benefits associated with two or more competing alternatives. A modeling study would also provide health outcomes that synthesize multiple sources of evidence, focusing on those outcomes most relevant to decisionmakers, and is well suited to address gaps in the literature. Exceptions would be cases where the interventions of interest have all been evaluated in head-to-head clinical trials with multiple study endpoints that capture all of the important outcomes in a diverse study cohort. That being said, because a modeling study requires significant time and resources, it is prudent to consider those situations where a modeling study would be most useful in order to weigh the relative costs and benefits of moving forward with a modeling exercise. A relatively quick review of the literature could be done to get a brief scan of the state of the evidence for a particular topic of interest. The following paragraphs discuss specific settings in which a modeling study would likely add substantial value alongside a systematic review.

#### High Degree of Uncertainty in Evidence

Models are well suited for research questions in which there is a high degree of uncertainty in assumptions or input parameters or situations in which there is a great amount of discordance among empirical studies. Although decisionmakers are often interested in comparing several medical interventions in a particular setting, it is unlikely that all interventions have been compared in head-to-head trials, and there may be several different study designs and study populations across the different intervention studies. Models provide a transparent structure that represents the natural history of the disease of interest, and can specify how an intervention affects the natural history process in terms of both benefits and harms. For example, we have excellent clinical trial evidence regarding the effectiveness of annual fecal occult blood testing for colorectal cancer screening, but no direct evidence on the effectiveness of screening with colonoscopy every 10 years. Models have been shown to be well suited for evaluating the effectiveness of different cancer screening strategies in a variety of settings.

#### Intermediate Outcomes

Several intervention studies use intermediate, or surrogate, outcomes as endpoints. Surrogate endpoints are often desirable in a trial setting because they are either more likely to occur or they occur much sooner (or both) than the terminal outcome of interest (e.g., disease-specific mortality), and thus a study can be conducted in a shorter timeframe with smaller sample sizes. However, decisionmakers are interested in terminal outcomes that have a significant impact on patients. Studies with long-term or terminal outcomes are often inconclusive, not feasible to conduct, or still being conducted. Models are beneficial in these situations. For example, trials that evaluate interventions for patients with insulin-dependent diabetes often use intermediate outcomes such as retinopathy and neuropathy, because they are more common and more immediate. Decisionmakers interested in comparing alternative therapies for patients with insulin-dependent diabetes are also interested in the outcomes of blindness and amputation. Decision models are well suited to providing information on these outcomes because they synthesize the studies using intermediate results with epidemiological data on the relationship between intermediate and terminal outcomes, in this case, retinopathy and risk of blindness, and/or neuropathy and the risk of amputation.

#### Specific Subpopulations

Intervention studies are often focused on a highly selected population, and may exclude individuals such as those who are older or have comorbidities. In these situations, modeling can be used to simulate findings where subpopulation characteristics are believed to impact conclusions for that specific population. For example, a model would be appropriate to examine the benefits and harms of warfarin therapy in a subpopulation of patients not studied in a clinical trial, such as elderly patients at risk of falling.

#### Relevant Outcomes

The comparison of strategies typically involves the evaluation of benefits and harms (and costs) of available interventions. The establishment of net benefit (i.e., benefit less harms) or cost effectiveness can be determined through the use of a decision model. Models are also useful for incorporating variables that may be important in evaluating the benefit or cost of an intervention in real-world settings. For example, intervention studies don't always incorporate actual adherence rates; they may include a simplifying assumption of perfect adherence.

#### Diagnostic Test Strategies

Models are perhaps best suited for evaluating diagnostic tests or test strategies. Studies that evaluate diagnostic tests focus on estimating test characteristics (sensitivity and specificity) and not on long-term outcomes. However, the clinical value of performing one diagnostic test over another, or a sequence of diagnostic tests, should be judged by comparing long-term benefits and harms. Decision models incorporate the underlying risk that an individual has the disease and simulate the progression (natural history) of the disease over time to track the relevant terminal outcomes. A diagnostic test that detects the presence of disease (i.e., true positive result) will result in the patient getting treated and, depending on the effectiveness of that treatment; the diagnostic test will result in an overall benefit. A diagnostic test can also falsely detect disease (i.e., false positive result), which would lead to some degree of harm by inappropriately treating such an individual.

#### Value of Information

There is great interest in the benefits modeling can bring to determining the value of information and specification of research priorities and directions. In many cases, systematic reviews conclude with recommendations for further research and models can be used to quantify the “value” that an additional research recommendation would contribute to the key questions of interest. This is typically done in the setting of cost-effectiveness analysis.

### Timing of Modeling Studies

When to conduct a modeling project in connection with a systematic review is a concern. Ideally, one would complete the systematic review first and then develop/refine a decision model that is designed to optimize the use of the evidence results. For example, the final results from a systematic review could inform modeling decisions about ways to categorize a disease that maximizes the use of the evidence. Or the results may indicate several options for categorizing a disease that would allow the modelers to build in different structural assumptions that could be evaluated in sensitivity analyses. This ideal situation, however, is unlikely to happen in practice and the modeling work will likely need to be completed at the same time, or close to the same time, as the systematic review. This is not an insurmountable problem and it is reasonable to assume that, with adequate interactions between the systematic review team and the modeling team, the modeling work could be done concurrently with the systematic review, with interim model parameter estimates used prior to completion of the reviews. Figure 1 illustrates this framework.

Figure 1 Diagram of framework

Figure 1 is a diagram of a framework that maps the decision process for when to use a model. Ultimately, the use of a model depends on the goal of the stakeholder. If the stakeholder's goal is evidence focused, modeling is not recommended. If the goal is decisionmaking focused, and the stakeholder is familiar enough with modeling to make good use of the model and model results, then modeling is recommended. However, if problem attributes are not likely to benefit from modeling, then the modeling process should be delayed until such time as benefits are more likely to accrue.

### Who Does the Modeling?

Although decision models provide synergies with systematic reviews, the skills required to develop and analyze decision models are not well represented by researchers who conduct systematic reviews. Because decision modeling requires a different skill set, it is not always feasible to have the modeling work done by systematic review research teams, such as EPCs. Modeling is a multidisciplinary field that requires several disciplinary experts in order to conduct a credible modeling analysis on a wide variety of topics on timelines typical of a systematic review. It is beneficial for those conducting the modeling to have frequent interactions with researchers conducting the systematic review to ensure that the model is developed in such a way to incorporate the synthesized data, and that all relevant data are collected and synthesized to inform the model structure. In the ideal circumstance, the systematic review team and the decision analysis team would reside in the same place in order to facilitate a close working relationship.

### Evaluating Existing Models

There are several checklists available for evaluating decision models. However, it is often difficult to judge whether published models adhere to the criteria because they are left to the interpretation of the reviewer. For example, one suggested criterion for model structure is that it “reflect the underlying biological process of the disease,” which may be difficult to judge in many cases. Table 16 provides a slight modification of the framework proposed by Philips et al. (2004),40 which is among the most comprehensive to date. A checklist such as this can help distinguish “good” models from “bad” models to some degree. However, if we focus on using models to assist the decisionmaker, a “good” model is one that includes inputs and outputs that are relevant and ultimately useful to the decisionmaker.

Table 16 Framework for quality assessment of decision models, modified from that proposed by Philips et al. (2004)40

Dimension of Quality | Questions for Critical Appraisal
Structure
Statement of decision problem | Is there a clear statement of the decision problem? Is the objective of the evaluation and model specified and consistent with the stated decision problem? Is the primary decisionmaker specified?
Statement of perspective | Is the perspective of the model stated clearly? Are the model inputs consistent with the stated perspective? Are the outcomes of the model consistent with the perspective and overall objective of the model?
Rationale for structure | Has the evidence regarding the model structure been described? Is the structure of the model consistent with a coherent theory of the health condition under evaluation? Have any competing theories regarding model structure been considered? Are the sources of data used to develop the structure of the model specified? Are the causal relationships described by the model structure justified appropriately?
Structural assumptions | Are the structural assumptions transparent and justified? Are the structural assumptions reasonable given the overall objective and perspective of the model?
Strategies/comparators | Is there a clear definition of the options under evaluation? Have all feasible and practical options been evaluated? If not, is there justification for the exclusion of feasible options?
Model type | Is the chosen model type appropriate given the decision problem and specified causal relationships within the model?
Time horizon | Is the time horizon of the model sufficient to reflect all important differences between options? Is the time horizon of the model, the duration of treatment, and treatment effect described and justified? Has a lifetime horizon been used? If not, has a shorter time horizon been justified?
Disease states/pathways | Do the disease states (state transition model) or the pathways (decision tree model) reflect the underlying biological process of the disease in question and the impact of interventions?
Cycle length | Is the cycle length defined and justified in terms of the national history of disease and the interventions being evaluated?
Data
Data identification | Are the data identification methods transparent and appropriate given the objectives of the model? Where choices have been made between data sources, are these justified appropriately? Has particular attention been paid to identifying data for the important parameters in the model? Has the process of selecting key parameters been justified and systematic (though not necessarily comprehensive) methods used to identify the most appropriate data? Has the quality of the data been assessed appropriately? Where expert opinion has been used, are the methods described and justified?
Premodel data analysis | Is the premodel data analysis methodology based on justifiable statistical and epidemiological techniques?
Baseline data | Is the choice of baseline data described and justified? Are transition probabilities calculated appropriately? Has a half cycle correction been applied? If not, has the omission been justified?
Treatment effects | If relative treatment effects have been derived from trial data, have they been synthesized using appropriate techniques? Have the methods and assumptions used to extrapolate short-term results to final outcomes been documented and justified? Have alternative assumptions been explored through sensitivity analysis? Have assumptions regarding the continuing effect of treatment once treatment is complete been documented and justified? Have alternative assumptions been explored through sensitivity analysis?
Quality of life weights (utilities) | Are the utilities incorporated into the model appropriate? Is the source for the utility weights referenced? Are the methods of derivation for the utility weights justified?
Data incorporation | Have all data incorporated into the model been described and referenced in sufficient detail? Are the assumptions and choices made in cases of mutually inconsistent data been justified? Is the process of data incorporation transparent? If data have been incorporated as distributions, has the choice of distribution for each type of parameter been described and justified? If data have been incorporated as distributions, is it clear that second-order uncertainty is reflected?
Assessment of parameter uncertainty | Are the methods of assessment of parameter uncertainty appropriate? Has probabilistic sensitivity analysis been done? If not, has this been justified? If data are incorporated as point estimates, are the ranges used for sensitivity analysis stated clearly and justified?
Assessment of structural uncertainty | Is there evidence that structural uncertainties have been addressed via sensitivity analysis?
Heterogeneity | Has heterogeneity been dealt with by running the model separately for different subgroups?
Consistency
Internal consistency | Is there evidence that the mathematical logic of the model has been tested thoroughly before use?
External consistency | Are the conclusions valid given the data presented? If the model has been calibrated against independent data, have any differences been explained and justified? Have the results of the model been compared with those of previous models and any differences in results explained?

Evaluating the model structure, including assumptions made, and assessing the completeness and quality of the input data (as described in Table 16) are clearly important components to evaluating models. However, it is also important to recognize that models can be very effective in predicting what could happen even when faced with limitations in the quality of the input data. In addition, for models that are evaluated for potential use alongside a systematic review, the quality of the input data is less relevant since much of the input data will come from the systematic review. A model that has a well-grounded structure (i.e., much is known about the biological nature of the disease) can be used to systematically vary the key parameters over plausible ranges to inform further studies needed to refine estimates of such key parameters.

All modeling efforts, at a minimum, should clearly display and discuss: (1) testing performed on the model (both structure and results), (2) assumptions and their impact on the results, (3) data input and parameters and their joint impact on the results, and (4) key drivers of the results. The latter point is important as, usually, a handful of key elements drive the results of a model. Those need to be made very explicit and such discussion should make sense to clinicians who are expert in the clinical domain addressed by the model and should be consistent with the underlying theory and natural history of the disease and its progression.

The involvement of clinical experts in the development of the model should be evident especially as it relates to the natural history of the disease; the formalization of the disease progression; the identification of, and rationale for relationships between key variables; and other “a priori structuring” tasks. Ideally, a visual depiction of the underlying disease mechanics would enhance the perception of content validity of the resulting model.

Just as the development of a model should integrate modeling and clinical expertise, the evaluation of a model needs to be conducted by both modeling and clinical experts. A modeler without the proper clinical expertise would naturally focus solely on the technical aspects of the model, but, if unfamiliar with the clinical domain, would not be in a position to judge face validity. A clinical expert would be in a position to judge whether the clinically important decision points have been captured and whether the underlying disease theory is appropriately integrated into the structure of the model.

This section focuses on the evaluation of existing models; Best Practices for Decision and Simulation Modeling focuses on best practices for developing new models.

### Model Outcomes

Model outcomes should always include those deemed relevant by the decisionmaker. Relevant outcomes should be discussed at the start of the modeling project with a skeleton table of anticipated results. These should include both short-term and long-term measures that are considered by the decisionmaker to be of particular value to his or her decisionmaking process. We also recommend a standard set of model output be developed to help with comparisons across models and aid in the acceptance of models over time. We recommend that quality-adjusted life years (QALYs) be included as standard output, even though this may not be best understood by the decisionmaker. In addition, life years (LYs) should also be included, as well as output that adds insight into the differences between the QALYs and LYs. For example, model output on the average amount of time spent in different health states should be provided, i.e., QALYs are a weighted average of the time spent in each health state and the quality-of-life weight assigned to each state. Also it should be clearly stated whether these are outcomes from a lifetime horizon or a short-term horizon and, when possible, a lifetime horizon should be included in the set of outcomes. When relevant, event outcomes should be provided in the outcomes table; for example, the lifetime risk of a simulated patient experiencing a particular event for each of the strategies being evaluated. Ultimately, there is a need for standard output tables and figures presented in a specific form and containing a standardized set of information and data regarding the model, sensitivity analyses, and reported outputs.

### Training

ARHQ is already an important funder of training decision analysts. The T32 training grant mechanism in health services research has funded many predoctoral students and postdoctoral fellows at universities that have a training program in health decision sciences. Unfortunately, only a limited number of universities offer comprehensive coursework in decision analysis and decision modeling. There are other training needs that focus more on the users of decision models, including seminars for systematic reviewers and potential stakeholders and policy makers. Opportunities for educating potential users of decision models would be created by the incorporation of a mechanism to conduct modeling with systematic reviews as a result of the interactive nature of the proposed framework. Specifically, the modeling teams would be required to communicate the value of the decision modeling approach in a way that appeals to and is understood by the non-modeling community. While it would never be expected that policy makers would understand the details of the model, it is necessary that they understand and trust the output from the models.

### Communication

Part of the challenge to using decision analyses for real-world decisionmaking has been in communicating their value to policymakers and other non-decision analysts. The issue with the acceptance of modeling is that modeling has been used extensively in cost-effectiveness analyses and thus is linked to the “rationing of health care.” The use of modeling may be viewed as one step in that direction. Much of the success of the impact that the Cancer Intervention and Surveillance Modeling Network models have had on health policy has been influenced by the communications efforts by the National Cancer Institute with other federal agencies.

## Future Recommendations

Table 17 lists some recommendations for future work in the areas of: (1) the role of modeling alongside systematic reviews, (2) standardized model output, (3) model validity guidelines, (4) training and communication, and (5) development of a modeling database.

Table 17 Future recommendations

Topic Area | Results Current Project | Future Recommendation
Role of modeling alongside systematic reviews | General support that this would be a beneficial endeavor. | The general guidance provided in the proposed framework would need to be refined as experience with the process of conducting modeling studies with systematic reviews is accumulated.
Standardized model output | There is not a currently agreed-upon list of model outputs, or a structured set of tables or figures that are recommended. | Model output should be, in part, determined by decisionmakers as part of a focused effort to learn what outputs decisionmakers value.
Model validity guidelines | The existing checklists do not identify fatal flaws of a model (e.g., asymmetries). | Further develop best practice guidelines to help determine how best to assess model validity.
Training and communication | There is a need for more training in decision modeling, particularly with users of models. Their value and results are not well understood by potential users, which limits the opportunity to impact real-world policymaking. | Modeling workshops. Further refinement of “Decision Modeling 101” presentation. Development of ways to communicate findings from modeling studies.
Modeling database | Potential for valuable resource. | Recommend a focused research effort to develop and test a modeling database.