# References and Included Studies

1 Tversky A, Kahneman D. Judgment under uncertainty: heuristics and biases Science. 1974;185(4157):1124-1131.
2 Rittenhouse B. Uses of models in economic evaluations of medicines and other health technologies. London. Office of Health Economics. 1996.
3 Albert DA. Decision theory in medicine: a review and critique. Milbank Mem Fund Q Health Soc. 1978;56(3):362-401. [pmid: 100721].
4 von Neumann J, Morgenstern O. Theory of Games and Economic Behavior. Third ed. Princeton. Princeton University Press. 1953.
5 Ledley RS, Lusted LB. Reasoning foundations of medical diagnosis; symbolic logic, probability, and value theory aid our understanding of how physicians reason. Science. 1959;130:9-21. [pmid: 13668531].
6 Henschke UK, Flehinger BJ. Decision theory in cancer therapy. Cancer. 1967;20(11):1819-1826. [pmid: 6061617].
7 Ingelfinger FJ. Decision in medicine. N Engl J Med. 1975;293(5):254-255. [pmid: 1143307].
8 Weinstein MC, Fineberg HV, Elstein AS, et al. Clinical Decision Analysis. Philadelphia. WB Saunders Company. 1980.
9 Beck JR, Pauker SG. The Markov process in medical prognosis. Med Decis Making. 1983;3(4):419-458. [pmid: 6668990].
10 Sonnenberg FA, Beck JR. Markov models in medical decision making: a practical guide. Med Decis Making. 1993;13(4):322-338. [pmid: 8246705].
11 Petitti DB. Meta-Analysis, Decision Analysis, and Cost-Effectiveness Analysis. Methods for Quantitative Synthesis in Medicine. 2 ed. New York, NY. Oxford UP. 2000.
12 Kassirer JP, Moskowitz AJ, Lau J, et al. Decision analysis: a progress report. Ann Inter Med. 1987;106(2):275-291.
13 Russel LB. Educated Guesses: Making Policy About Medical Screening Tests. Los Angeles. University of California Press. 1994.
14 Mulrow C, Langhorne P, Grimshaw J. Integrating heterogeneous pieces of evidence in systematic reviews. Annals of Internal Medicine. Dec. 1. 1997;127(11):989-995. [pmid: 9412305].
15 Brennan A, Chick SE, Davies R. A taxonomy of model structures for economic evaluation of health technologies. Health Economics. Dec. 2006;15(12):1295-1310. [pmid: 16941543].
16 Brisson M, Edmunds WJ. Economic evaluation of vaccination programs: The impact of herd-immunity. Med Decis Making. 2003;23(1):76-82. [pmid: 12583457].
17 Elbasha EH, Dasbach EJ, Insinga RP. Model for assessing human papillomavirus vaccination strategies. Emerging Infectious Diseases. Jan. 2007;13(1):28-41. [pmid: 17370513].
18 Jun JB, Jacobson SH, Swisher JR. Application of discrete-event simulation in health care: A survey. J Opl Res Soc. 1999;50(2):109-123.
19 Stahl JE, Rattner D, Wiklund R, et al. Reorganizing the system of care surrounding laparoscopic surgery: A cost-effectiveness analysis using discrete-event simulation. Med Decis Making. 2004;24(5):461-471. [pmid: 15358995].
20 Marjamaa RA, Torkki PM, Hirvensalo EJ, et al. What is the best workflow for an operating room? A simulation study of five scenarios. Health Care Manage Sci. 2009;12(2):142-146.
21 Schwartz WB. Sounding board. Decision Analysis: a look at the chief complaints. N Engl J Med. 1979;300(10):556-559. [pmid: 763258].
22 Braithwaite RS, Roberts MS, Justice AC. Incorporating quality of evidence into decision analytic modeling. Ann Inter Med. 2007;146(2):133-141.
23 U.S. Preventive Services Task Force. Screening for colorectal cancer: recommendation and rationale. Am Fam Physician. 2002;66(12):2287-2290. [pmid: 12507168].
24 U.S. Preventive Services Task Force. Screening for colorectal cancer: U.S. Preventive Services Task Force recommendation statement. [Summary for patients in Ann Intern Med 2008 Nov 4;149(9):I-44; PMID: 18838719]. Ann Inter Med. Nov. 4. 2008;149(9):627-637.
25 Whitlock EP, Lin JS, Liles E, et al. Screening for colorectal cancer: a targeted, updated systematic review for the U.S. Preventive Services Task Force. Ann Inter Med. 2008;149(9):638-658.
26 Zauber AG, Lansdorp-Vogelaar I, Knudsen AB, et al. Evaluating test strategies for colorectal cancer screening: a decision analysis for the U.S. Preventive Services Task Force. Ann Inter Med. 2008;149(9):659-669.
27 Weinstein MC, Toy EL, Sandberg EA, et al. Modeling for health care and other policy decisions: Uses, roles and validity. Value Health. 2001;4(5):348-361. [pmid: 11705125].
28 Sculpher M, Fenwick E, Claxton K. Assessing quality in decision analytic cost-effectiveness models. A suggested framework and example of application. Pharmacoeconomics. May. 2000;17(5):461-477. [pmid: 10977388].
29 Bonis PA, Trikalinos TA, Chung M, et al. Hereditary Nonpolyposis Colorectal Cancer: Diagnostic Strategies and Their Implications. Evidence Report/Technology Assessment No. 150. (Prepared by Tufts-New England Medical Center Evidence-based Practice Center under Contract No.290-02-0022). Rockville, MD. Agency for Healthcare Research and Quality. May. 2007. AHRQ Publication No. 07-E008.
30 Lau J, Ioannidis JP, Balk E, et al. Evaluation of Technologies for Identifying Acute Cardiac Ischemia in Emergency Departments. Evidence Report: Technology Assessment No. 26. (Prepared by The New England Medical Center Evidence-based Practice Center under Contract No. 290-97-0019). Rockville, MD. Agency for Healthcare Research and Quality. September. 2000. AHRQ Publication No. 01-E006.
31 Lau J, Zucker D, Engels EA, et al. Diagnosis and Treatment of Acute Bacterial Rhinosinusitis. Evidence Report: Technology Assessment No. 9. (Prepared by New England Medical Center Evidence-based Practice Center under Contract No. 290-97-0019). Rockville, MD. Agency for Healthcare Research and Quality. March. 1999. AHRQ Publication No. 99-E016.
32 Trikalinos TA, Lau J. Obstructive Sleep Apnea-Hypopnea Syndrome: Modeling Different Diagnostic Strategies. Technology Assessment. (Prepared by Tufts-New England Evidence-based Practice Center under Contract No. 290-02-0022). Rockville, MD. Agency for Healthcare Research and Quality. December. 2007.
33 Matchar DB, Thakur ME, Grossman I, et al. Testing for Cytochrome P450 Polymorphisms in Adults With Nonpsychotic Depression Treated With Welective Werotonin Reuptake Inhibitors (SSRIs). Evidence Report/Technology Assessment No. 146. (Prepared by the Duke University Evidence-based Practice Center under Contract No. 290-02-0025). Rockville, MD. Agency for Healthcare Research and Quality. January. 2007. AHRQ Publication No. 07-E002.
34 Myers ER, Bastian LA, Havrilesky LJ, et al. Management of Adnexal Mass. Evidence Report/Technology Assessment No. 130. (Prepared by the Duke University Evidence-based Practice Center under Contract No. 290-02-0025). Rockville, MD. Agency for Healthcare Research and Quality. February. 2006. AHRQ Publication No. 06-E004.
35 Myers ER, Havrilesky LJ, Kulasingam SL, et al. Genomic Tests for Ovarian Cancer Detection and Management. Evidence Report/Technology Assessment No. 145. (Prepared by the Duke University Evidence-based Practice Center under Contract No. 290-02-0025). Rockville, MD. Agency for Healthcare Research and Quality. October. 2006. AHRQ Publication No. 07-E001.
36 Shekelle P, Morton S, Atkinson S, et al. Pharmacologic Management of Heart Failure and Left Ventricular Systolic Dysfunction: Effect in Female, Black, and Diabetic {atients, and Cost-Effectiveness. Evidence Report: Technology Assessment No. 82. (Prepared by the Southern California-RAND Evidence-based Practice Center under Contract. No. 290-97-0001). Rockville, MD. Agency for Healthcare Research and Quality. July. 2003. AHRQ Publication No. 03-E045.
37 McAlister F, Ezekowitz J, Wiebe N, et al. Cardiac Resynchronization Therapy for Congestive Heart Failure. Evidence Report: Technology Assessment No. 152. (Prepared by the University of Alberta Evidence-based Practice Center under Contract No. 290-02-0023). Rockville, MD. Agency for Healthcare Research and Quality. AHRQ Publication No. 07-E009.
38 Caughey AB, Sundaram V, Kaimal AJ, et al. Maternal and Neonatal Outcomes of Elective Induction of Labor. Evidence Report/Technology Assessment No. 176. (Prepared by the Stanford University-UCSF Evidence-based Practice Center under Contract No. 290-02-0017). Rockville, MD. Agency for Healthcare Research and Quality. March. 2009. AHRQ Publication No. 09-E005.
39 Chapell R, Reston J, Snyder D, et al. Management of Treatment-Resistant Epilepsy. Evidence Report: Technology Assessment No. 77. (Prepared by the ECRI Evidence-based Practice Center under Contract No. 290-97-0020). Rockville, MD. Agency for Healthcare Research and Quality. April. 2003. AHRQ Publication No. 03-0028.
40 Philips Z, Ginnelly L, Sculpher M, et al. Review of guidelines for good practice in decision-analytic modelling in health technology assessment. Health Technology Assessment. Sep. 2004;8(36):iii-iv. ix. xi. 1. 158. [pmid: 15361314].
41 Pignone M, Saha S, Hoerger T, et al. Challenges in systematic reviews of economic analyses. Annals of Internal Medicine. Jun. 21. 2005;142(12 Pt 2):1073-1079. [pmid: 15968032].
42 Annemans L. Methodological issues in evaluating cost effectiveness of adjuvant aromatase inhibitors in early breast cancer: a need for improved modelling to aid decision making. Pharmacoeconomics. 2008;26(5):409-423. [pmid: 18429657].
43 Campbell H, Briggs A, Buxton M, et al. The credibility of health economic models for health policy decision-making: the case of population screening for abdominal aortic aneurysm. Journal of Health Services & Research Policy. Jan. 2007;12(1):11-17.
44 Earnshaw SR, Wilson M, Mauskopf J, et al. Model-based cost-effectiveness analyses for the treatment of acute stroke events: a review and summary of challenges. Value in Health. Jun. 2009;12(4):507-520. [pmid: 19900253].
45 Green C. Modelling disease progression in Alzheimer's disease: a review of modelling methods used for cost-effectiveness analysis. Pharmacoeconomics. 2007;25(9):735-750. [pmid: 17803333].
46 Jones MT, Cockrum PC. A critical review of published economic modelling studies in depression. Pharmacoeconomics. Jun. 2000;17(6):555-583. [pmid: 10977394].
47 Pignone M, Saha S, Hoerger T, et al. Cost-effectiveness analyses of colorectal cancer screening: a systematic review for the U.S. Preventive Services Task Force. Annals of Internal Medicine. Jul. 16. 2002;137(2):96-104. [pmid: 12118964].
48 Economic Models of Colorectal Cancer Screening in Average-Risk Adults: Workshop Summary. Institute of Medicine and National Research Council. 2005.
49 Sonnenberg F, Clarke L. personal communication. 2010.
50 Decision analytic modelling in the economic evaluation of health technologies. A consensus statement. Consensus Conference on Guidelines on Economic Modelling in Health Technology Assessment. Pharmacoeconomics. May. 2000;17(5):443-444. [pmid: 10977386].
51 Philips Z, Bojke L, Sculpher M, et al. Good practice guidelines for decision-analytic modelling in health technology assessment: a review and consolidation of quality assessment. Pharmacoeconomics. 2006;24(4):355-371. [pmid: 16605282].
52 Tom E, Schulman KA. Mathematical models in decision analysis. Infection Control & Hospital Epidemiology. Jan. 1997;18(1):65-73. [pmid: 9013249].
53 Vale L, Thomas R, MacLennan G, et al. Systematic review of economic evaluations and cost analyses of guideline implementation strategies. European Journal of Health Economics. Jun. 2007;8(2):111-121. [pmid: 17347844].
54 Weinstein MC, O'Brien B, Hornberger J, et al. Principles of good practice for decision analytic modeling in health-care evaluation: report of the ISPOR Task Force on Good Research Practices--Modeling Studies. [see comment]. Value in Health. Jan-Feb. 2003;6(1):9-17. [pmid: 12535234].
55 Brennan A, Akehurst R. Modelling in health economic evaluation. What is its place? What is its value?. Pharmacoeconomics. May. 2000;17(5):445-459. [pmid: 10977387].
56 Drummond MF, Iglesias CP, Cooper NJ. Systematic reviews and economic evaluations conducted for the National Institute for Health and Clinical Excellence in the United Kingdom: a game of two halves?. International Journal of Technology Assessment in Health Care. 2008;24(2):146-150. [pmid: 18400116].
57 Oddone EZ, Samsa G, Matchar DB. Global judgments versus decision-model-facilitated judgments: are experts internally consistent?. [erratum appears in Med Decis Making 1995 Jul-Sep;15(3):230]. Medical Decision Making. Jan-Mar. 1994;14(1):19-26. [pmid: 8152353].
58 Briggs AH. Handling uncertainty in cost-effectiveness models. Pharmacoeconomics. May. 2000;17(5):479-500. [pmid: 10977389].
59 Claxton K, Eggington S, Ginnelly L, et al. A Pilot Study of Value of Information Analysis to Support Research Recommendations for the National Institute for Health and Clinical Excellence. Centre for Health Economics, University of York. 2005.
60 Cooper NJ, Sutton AJ, Ades AE, et al. Use of evidence in economic decision models: practical issues and methodological challenges. Health Economics. Dec. 2007;16(12):1277-1286. [pmid: 18034447].
61 Debicki D, Ferko N, Demarteau N, et al. Comparison of detailed and succinct cohort modelling approaches in a multi-regional evaluation of cervical cancer vaccination. Vaccine. Sep. 15. Suppl 5. 2008;26:F16-28. [pmid: 18992379].
62 Drummond M, Manca A, Sculpher M. Increasing the generalizability of economic evaluations: recommendations for the design, analysis, and reporting of studies. International Journal of Technology Assessment in Health Care. 2005;21(2):165-171. [pmid: 15921055].
63 Drummond M, Barbieri M, Cook J, et al. Transferability of economic evaluations across jurisdictions: ISPOR Good Research Practices Task Force report. Value in Health. Jun. 2009;12(4):409-418. [pmid: 19900249].
64 Duintjer Tebbens RJ, Thompson KM, Hunink MGM, et al. Uncertainty and sensitivity analyses of a dynamic economic evaluation model for vaccination programs. Medical Decision Making. Mar-Apr. 2008;28(2):182-200. [pmid: 18349438].
65 Evans C, Crawford B. Expert judgement in pharmacoeconomic studies. Guidance and future use. Pharmacoeconomics. Jun. 2000;17(6):545-553. [pmid: 10977393].
66 Faissol DM, Griffin PM, Swann JL. Bias in Markov models of disease. Mathematical Biosciences. Aug. 2009;220(2):143-156. [pmid: 19538974].
67 Gallivan S. Challenging the role of calibration, validation and sensitivity analysis in relation to models of health care processes. Health Care Management Science. Jun. 2008;11(2):208-213. [pmid: 18581827].
68 Hughes D, Cowell W, Koncz T, et al. Methods for integrating medication compliance and persistence in pharmacoeconomic evaluations. Value in Health. Nov-Dec. 2007;10(6):498-509. [pmid: 17970932].
69 Karnon J, Brennan A, Akehurst R. A critique and impact analysis of decision modeling assumptions. Medical Decision Making. Jul-Aug. 2007;27(4):491-499. [pmid: 17761961].
70 Lilford R, Girling A, Braunholtz D, et al. Cost-utility analysis when not everyone wants the treatment: modeling split-choice bias. Medical Decision Making. Jan-Feb. 2007;27(1):21-26. [pmid: 17237449].
71 McCabe C, Dixon S. Testing the validity of cost-effectiveness models. Pharmacoeconomics. May. 2000;17(5):501-513. [pmid: 10977390].
72 Stout NK, Knudsen AB, Kong CY, et al. Calibration methods used in cancer simulation models and suggested reporting guidelines. Pharmacoeconomics. 2009;27(7):533-545. [pmid: 19663525].
73 Sun X, Faunce T. Decision-analytical modelling in health-care economic evaluations. European Journal of Health Economics. Nov. 2008;9(4):313-323. [pmid: 17943332].
74 Swan JS, Miksad RA. Measuring the quality-of-life effects of diagnostic and screening tests. Journal of the American College of Radiology. Aug. 2009;6(8):567-575. [pmid: 19643385].
75 Tavakoli M, Davies HT, Thomson R. Decision analysis in evidence-based decision making. Journal of Evaluation in Clinical Practice. May. 2000;6(2):111-120. [pmid: 10970005].
76 Trikalinos TA, Siebert U, Lau J. Decision-analytic modeling to evaluate benefits and harms of medical tests: uses and limitations. Medical Decision Making. Sep-Oct. 2009;29(5):E22-29. [pmid: 19734441].
77 Bernstein SJ, Hofer TP, Meijler AP, et al. Setting standards for effectiveness: a comparison of expert panels and decision analysis. International Journal for Quality in Health Care. Aug. 1997;9(4):255-263. [pmid: 9304424].
78 Karnon J, Goyder E, Tappenden P, et al. A review and critique of modelling in prioritising and designing screening programmes. Health Technology Assessment. Dec. 2007;11(52):iii-iv. ix. xi. 1. 145. [pmid: 18031651].
79 Tappenden P, Chilcott J, Ward S, et al. Methodological issues in the economic analysis of cancer treatments. European Journal of Cancer. Nov. 2006;42(17):2867-2875. [pmid: 17023160].
80 Luce BR. Policy implications of modeling the cost-effectiveness of health care technologies. Drug Info J. 1995;29:1469-1475.