# Potential Modeling Resources

## Introduction

The purpose of systematic reviews is to synthesize the current scientific literature on a particular topic to assist public and private organizations in developing strategies that improve the quality of health care and decisionmaking. The resulting evidence reports may be used to inform practice guidelines, performance measures, educational programs, or coverage policies. Users of evidence reports include clinicians, health professional associations, health system managers, researchers, consumer organizations, policymakers, and other health stakeholders, such as the United States Preventive Services Task Force (USPSTF). Systematic reviews synthesize the existing evidence on a particular topic and thus may be limited by an incomplete evidence base. In cases where the stakeholders questions are not fully addressed by the evidence synthesis and when the questions asked by the stakeholders pertain to an action (e.g., what's the best course of action given the available data?) and not statements of truth (e.g., is one intervention statistically more effective than another?), the use of a decision analysis alongside the systematic review may be appropriate.

Using decision analysis alongside a systematic review requires one to ask different types of questions, ones that are less focused on evidence and more focused on decisionmaking and valued outcomes. Ideally, it requires a dialogue with the decisionmakers about their decisionmaking goals, and it lays out clearly and systematically the decision process, elements of the decision that are well supported by the evidence, elements that require explicit assumptions to be made, and results from sensitivity analyses that highlight which parameters and assumptions most influence the main findings.

Once it is determined that a modeling component would add substantial value to a systematic review, different approaches can be considered. We explore three such approaches in this chapter, and discuss some of the challenges. The first approach would be to conduct a systematic review of prior modeling studies on the topic of interest and provide a synthesis of the modeling study results to the decisionmaker(s). The search would attempt to find modeling studies that addressed the same questions, or similar questions, that the systematic review is addressing. A second approach would be to identify modeling groups that have an existing relevant model. Existing consortia or informal groups of modelers for some diseases could serve as a good resource. The Cancer Intervention and Surveillance Modeling Network (CISNET), funded by the National Cancer Institute, is a consortium of cancer modelers that has been involved in several analyses for national coverage determinations for the Centers for Medicare & Medicaid Services and guideline development by the USPSTF. The Collaborative Obesity Modeling Network (COMNet), funded by the National Institutes of Health and Robert Wood Johnson Foundation, consists of modeling groups from around the world (United States, Canada, United Kingdom, and Australia) who use simulation models to predict changes in population obesity trends and assess the cost-effectiveness of specified interventions to reduce obesity. A third approach would be to develop a de novo model (note there is some overlap in what might be considered a de novo model vs. a revision of an existing model). Table 18 summarizes these approaches.

Table 18 Approaches to conducting a modeling study alongside a systematic review

Approach | Advantages | Disadvantages
Conduct a systematic review of modeling studies | Provides a good first step to understanding the modeling issues pertaining to a disease/treatment area. | May not fit question precisely. Does not allow input from stakeholders.
Collaborate with investigators with existing model(s) | Allows for input from stakeholder. | May involve significant reprogramming in certain cases.
Develop model de novo | Allows for input from stakeholder; no influence from prior modeling assumptions. | May be time consuming and more costly.

## Comparison of Approaches

### Conduct a Systematic Review of Modeling Studies

At present, there are no rigorous methods for synthesizing and reporting modeling studies. Pignone and colleagues discuss the challenges associated with conducting systematic reviews of economic evaluations, much of which is relevant to decision analyses.41 The challenge of identifying papers in the literature that use a decision analysis model was addressed in the Overview of Decision Models Used in Research section of this report, that is, what is a good search algorithm? One of the challenges in selecting papers to review among those identified from the initial search is to set the inclusion criteria broad enough to identify a sufficient number of papers to review (which tend to be small in number), yet have sufficiently stringent exclusion criteria to eliminate the low-quality papers, although there is no good system of grading models per se. While there are checklists for basic elements that should be included in a decision modeling study, such as “statement of the problem” and “list of assumptions,”28,40 the overall quality of the model is a subjective assessment by the reviewer.

Assessing the quality of a model requires addressing the multiple categories of criteria, each of which must be assessed separately across several elements. For example, the category pertaining to model structure assesses the degree to which a model accurately reflects the natural history of disease, or whether the causal linkages between variables are explained and justified. Another category, which requires an independent assessment, pertains to data inputs into the model. This assessment determines whether data sources are clearly identified and level of evidence provided, as well as whether suitable justification is provided for base case values and ranges used in sensitivity analysis. A model could have high-quality structure and low-quality data inputs, and vice versa. A third dimension that is important in determining the quality of a model is the validation, that is, the degree to which a model has been “tested.” This validation can range from simple debugging exercises to efforts to compare model output with other relevant studies.

Because decision-analytic studies vary in terms of the methods used (type of model, how or if natural history is defined, choice of defining and categorizing health states, choice of time horizon, etc.) the synthesis of model results can be problematic. Because the goal of a decision analysis is to assist in decisionmaking and not in making inferences, methods that combine results and provide confidence bounds are less relevant. Another disadvantage of this approach is that it does not allow the stakeholder to have any input. Again, because there are several modeling options when developing a decision model, the choices made by the analyst may not be consistent with the values and preferences of the decisionmaker/stakeholder. More importantly, the process of constructing a decision model interactively with the decisionmaker helps with the decisionmaker's understanding of the model and builds trust in the model results (In this report, see Use of Modeling in Systematic Reviews: The EPC Perspective, and Best Practices for Decision and Simulation Modeling).

Several review papers of cost-effectiveness decision models have addressed specific disease areas.42-46 However, the goal of those papers was not to summarize the findings (e.g., report a synthesized estimate and range of the incremental cost-effectiveness ratio or the incremental gain in quality-adjusted life expectancy of an intervention compared with a standard) as one would do in a systematic review of the evidence. Instead, the goal of those reviews was to compare and contrast the different approaches to modeling and to generate recommendations for best modeling practices. Table 2 summarizes five modeling review papers.

Although the types of reviews shown in Table 19 would not provide the necessary modeling information needed to supplement a systematic review, they do provide essential background information to any modeling endeavor requested by AHRQ, as well as identify existing modelers within a disease area. In fact, an initial review of models led to the modeling work that was done to assist the USPSTF in the updating of the 2008 recommendations for colorectal cancer screening. For the 2002 Task Force recommendations, Pignone and colleagues conducted a systematic review of the cost-effectiveness analysis studies of colorectal cancer screening.47 They concluded that there was consensus among all of the studies that colorectal cancer screening was cost effective but there was no consensus regarding which strategy was optimal. They suspected the discrepancies were because of different assumptions in modeling the natural history of the disease, and also different estimates used for the input parameters. The findings from that review paper provided motivation for the Institute of Medicine (IOM) Workshop on Economic Models of Colorectal Cancer Screening,48 which was convened to explore the discrepant findings across cost-effectiveness colorectal cancer screening models, using five of the models identified in the review. The workshop results showed that the discrepancies across models could be reduced somewhat by standardizing the inputs on adherence, test characteristics, costs, and follow-up assumptions. However, it was unable to further evaluate the uncertainties in the (untestable) natural history assumptions across the different models, such as adenoma dwell time. Two of the modeling groups that participated in the workshop conducted the decision analysis that provided outcomes to the USPSTF in 2008, and are part of the colorectal cancer CISNET group.26

Table 19 Examples of reviews of models

First Author, Year, Search Detail | Health Condition Model Type | Number of Models A Priori Model Definition | Disease Specific Key Modeling Aspects | Quality Indicators | Findings/Recommendations for Model Practice
Earnshaw, 2009^44^ Searched 1990-2007 | Acute stroke Treatment: treatment strategies or therapeutic intervention | 13 models Markov models, decision-tree models, models based on mathematical equations | Model approach and health states; transition probabilities, short-, long-term, and indirect costs, utilities, post-stroke mortality, time horizon, model validation, estimation of parameter uncertainty | Not developed Summary and critical assessment per paper; criteria not provided | - Keep model complexity to minimum to avoid assumptions not supported by data; - Use two phase models: acute treatment, long-term management and prevention; - Report results in lifetime incremental cost per QALY; - Include both one-way and probabilistic sensitivity analysis
Annemans, 2008^42^ No dates provided | Breast cancer Treatment: aromatase inhibitors in early cancer | 13 models Definition not reported | Absolute incidence of recurrence in control arm, risk reduction with intervention; cost of intervention; adverse events; patient subtypes | Model structure assessment guided by ISPOR modeling guidelines (Weinstein 2003) | - Work toward developing generic model that can evaluate both direct and indirect comparisons.; - Models should be peer reviewed and made available with open access.; - Calibrate with observational data; - Multiple specific suggested elements which models should take into account
Campbell, 2008^43^ Through 2005 | Abdominal aortic aneurysm Screening: ultrasound of elderly males | 9 models Definition not reported | | Model structure assessment guided by HTA modeling guidelines (Philips 2004) | - Lack of agreement between models raises question of overall quality of models; - Insufficient details of model inputs and structure inhibit validity assessment
Green, 2007^45^ Through 2005 | Alzheimer's disease Treatment: cost-effectiveness of drug treatments | 22 CEAs, 20 models Use “clinical, economic, and epidemiological data” to study progression over time | | Critical appraisal guided by Drummond et al. (1997) (Novel use of table data) | - 19 of the 20 models were supported by pharmaceutical industry; - Literature is varied and models were largely drug-specific; - Data inputs are sparse in all areas (epidemiology, resource use, outcomes) and clinical trials are all short term; - Link between clinical effectiveness and modeling of longer term outcomes is not clear or explicit in many publications
Jones, 2000^46^ No dates provided | Depression Treatment: antidepressants | 10 models Definition not reported | Provided suggested decision tree, 5 year timeframe, impact of drugs coming off patent, depression severity, and other depressive disorders | Not developed. Summary and critical assessment per paper; criteria not provided | - Provides overall status of antidepressant modeling literature, examples of all relevant drugs and common modeling techniques; - Intended audience is model user

QALY = quality-adjusted life year; ISPOR = International Society for Pharmacoeconomics and Outcomes Research; HTA = health technology assessment; CEAs = cost-effective analysis.

### Collaborate With Investigators With Existing Models

The decision to collaborate with investigators who have existing models may require some compromise to avoid the time and resources it takes to develop a simulation model from scratch. It may mean using a model that does not fit precisely, but it can allow for an interactive approach between the modeling group(s) and the stakeholder, as well as the systematic review team. As a first step in identifying a modeler or modeling group with an existing model, one could use the search algorithm developed in Overview of Decision Models Used in Research with a specified range of years and disease or condition. A review and abstraction of the articles found through this process would yield a summary of existing models that would compare several features of the models including: model design, time horizon, health states or health pathways (natural history), list of assumptions, health outcomes, uncertainty, and validation. Brief reports that summarize the existing modeling literature could be of value to the stakeholder(s) in understanding the range of model structures, modeling assumptions, data inputs, and model results for a particular topic. In addition, in-person workshops, similar to the two-day IOM workshop on models for colorectal cancer screening, could serve as an instructive first step for modelers and stakeholders.

To assist in identifying existing modelers, we explored the potential value of a modeling database that includes some basic details about the existing models in the literature. The modeling field has been interested for some time in developing a Web-based model registry platform.49 To explore the time required to develop such a database, and the potential data fields to collect, we reviewed a subset of the 2009 modeling papers identified in Overview of Decision Models Used in Research to determine whether the model was appropriate for further data abstraction. We used two criteria: (1) natural history or slightly modified natural history (e.g., under usual care) was modeled, and (2) the model was complex enough to be flexible and generalizable in several settings. We collected the following information on a data-auditing form for each identified article:

- Reference citation
- Base-case population
- Strategies evaluated
- Model type
- Time horizon
- Cycle length
- Health outcomes
- Probabilistic sensitivity analysis (yes/no)
- Validation (yes/no)
- Model parameters (N=natural history; E=effectiveness; R=risk).

We noted the description of the model parameters included, usually as presented in the article's Table 1 (which, by convention, typically lists key model parameters, base case value, and ranges used in sensitivity analyses), but did not abstract any values, as we would expect those to come from a companion systematic review. We used three identifiers to distinguish the type of model parameter: (1) those that model the natural history of disease (N), (2) those that model the effectiveness of the intervention (E), and (3) those that model the risks of the intervention (R).

Among the papers published in 2009 that included a model, a subset was selected for further data abstraction. Abstracted information is shown in Appendix F. Such a database of abstracted information, once fully developed and maintained, could serve as a resource to determine if and how many models exist on a particular disease area. It also could identify investigators who could potentially conduct the decision modeling exercise alongside a systematic review. Another benefit of this type of resource is to identify multiple groups with models developed for the same or similar purposes to conduct comparative modeling. In comparative modeling, independently developed models are used to address the same clinical or policy question, which provides a type of sensitivity analysis on the underlying modeling assumptions made by the model developers.

### Develop a De Novo Model

This approach requires the most time and resources, though it would provide the most flexibility and opportunity for input from the stakeholder and the systematic review team. This approach is optimal in cases where the structure of existing models is not flexible enough to simulate the interventions of interest. For example, suppose we are interested in a model that simulates the health outcomes of hypertension screening followed by targeted treatment for several pre-specified blood pressure levels. Markov models that simulate hypertension screening would have categorized levels of blood pressure, and likely include only systolic or diastolic levels. If the categories are not consistent with the targeted levels for treatment, the model would essentially need to be re-specified and re-parameterized.

### Practical Considerations

#### EPCs

This report focuses on conducting a simulation modeling analysis in conjunction with a systematic review. One resource for conducting systematic reviews is the EPCs. While all of the EPCs have expertise in the areas of conducting systematic reviews, they do not all have expertise in decision modeling. CISNET is an example of coordinated modeling efforts that legitimize and promote use of models. Similar benefits may be found with other disease groups or policy/decisionmaking bodies.

#### Timing

The issues surrounding the timing of when a decision analysis is conducted alongside a review pose several challenges. Ideally, a decision analysis would not be done unless it was deemed to add substantial value to the questions being addressed by the systematic review. This may not become clear until after the systematic review has begun. However, it typically takes about the same time to develop and analyze a decision model as it does to conduct a systematic review, and the final decision analysis results should incorporate the results from the review. Thus the addition of a simulation model alongside a systematic review may add time to the overall project in some cases.

## Summary

Three basic options are available for conducting a modeling study alongside a systematic review. One option is to use methods similar to the systematic review and summarize and synthesize the available modeling studies on a particular topic. This approach provides a good first step to understanding the modeling issues pertaining to a disease and treatment area, but has several limitations in that it may not fit the question precisely and it does not allow for input from the stakeholders. A second approach is to collaborate with investigators with existing models. This approach requires modelers to be willing to make changes to their models that are consistent with the values of the stakeholder, which may involve significant reprogramming in some cases. The third approach is to develop de novo models. A key advantage to this approach over using existing models is that it limits any influence from prior modeling assumptions and allows perhaps more unbiased input from the stakeholder and the systematic review. This approach would be the most time consuming and costly, and it may not be appropriate for disease areas that require a fairly sophisticated modeling approach (e.g., cancer screening strategies) because of the time required for model development.