# Overview of Decision Models Used in Research

## Introduction

Decision analysis is a systematic, quantitative, and transparent approach to making decisions under uncertainty. The fundamental tool of decision analysis is a decision-analytic model, most often a decision tree or a Markov model. A decision model provides a way to visualize the sequences of events that can occur following alternative decisions (or actions) in a logical framework, as well as the health outcomes associated with each possible pathway. Decision models can incorporate the probabilities of the underlying (true) states of nature in determining the distribution of possible outcomes associated with a particular decision. These probabilities are not known to the decisionmaker but are critically important. For example, the value associated with the decision to do a diagnostic test depends on the probability that the patient has the disease of interest (i.e., the prior probability of disease), which in turn determines the probabilities of true and false positive findings, as well as true and false negative findings. Ultimately, the relative values assigned to these different outcomes determine the clinical value of a test, for example, how bad is it to fail to treat a person with disease relative to treating a person without disease? While the evidence requirement for a diagnostic test focuses on its diagnostic performance (e.g., sensitivity, specificity), the clinical value of the test, which should underlie the decision to use or recommend the test, depends on clinical evidence well beyond measurements of test performance. For example, does the information obtained from the diagnostic test change the decision that would be made, and does this change in decision lead to improved health outcomes? The methods of decision analysis have been found to be particularly useful in settings where multiple data inputs from a variety of studies are relevant in a particular decisionmaking context.

Since the first application in 1967, decision-analytic models have been increasingly used to evaluate and compare competing public health and medical interventions. Decision models can vary from a very simple “back of the envelope” type of calculation to extremely complex computer-based microsimulation models. While the term “model” has different meanings in different clinical settings,27 such as a statistical model, the fundamental feature of a decision model is that the goal of a decision model is to assist with decisionmaking and not to make statements about truth. Statistical study designs such as randomized clinical trials and case control studies are focused on gathering evidence; however, decision analysis studies are aimed at processing evidence. In the absence of a systematic and formal approach that assists the decisionmaker in the processing of the (often disparate and complex) evidence, the processing occurs in a more informal way.

There has been little documentation of the use of decision models in the literature. Hence, the goal of our analysis was to profile decision-analytic models published in the literature over the past 5 years, and to provide a summary of who is publishing models, in what disease areas, in what journals, and for what types of interventions.

## Methods

### Overview

We sought to obtain a “bird's eye” view of the number of articles in the medical literature that used a model for medical decisionmaking purposes. Our goal was to capture studies that used the methods of decision analysis to project health outcomes associated with two or more competing strategies for purposes of decisionmaking. We were not interested in studies with a goal of estimating efficacy or effectiveness parameters, nor were we interested in studies that evaluation environmental interventions or regulatory policies. Our goal was to document the current use of decision models in the medical literature (within the past 5 years) and document basic information about the authors and analyses.

### Literature Search

We conducted a systematic review of the medical literature and the grey literature to document and synthesize all analyses that used a decision-analytic model, including relevant cost-effectiveness analyses, conducted within the past 5 years.

We searched Medline for articles that used some form of decision model. We relied on key word searches to locate decision models since medical subject headings (MeSH) terms are not well indexed for decision modeling topics. Searches employing a model term other than “decision analysis” or “decision analytic model” required filters to eliminate nonrelated articles. For these filters, we used some form of quality adjusted life OR some form of incremental cost effectiveness ratio OR some form of disability adjusted life OR some form of modeling technique to further specify related articles. In addition, since cost-effectiveness models are the most commonly noted form of economic modeling references in the literature, we created a filter to further limit cost-utility and cost-effectiveness models to those that were not reported as simple extensions of a single clinical trial, as these were viewed as not incorporating multiple sources of data. Articles were limited to English language and human subjects. The full search string is provided in Appendix A. The search was performed on October 15, 2009, with an update search performed on February 18, 2010, for articles published from 2005 through 2009.

#### Inclusion/Exclusion Criteria

Articles were not excluded by country of origin, type of disease condition, or treatment provided. We also did not include decision aids or statistical analyses for estimating effect size, inference, or prediction. We included cost-effectiveness analysis as long as the model was used to project the costs and the effectiveness of two or more strategies, but excluded papers that evaluated costs only. Since our focus was on the effectiveness/comparative effectiveness of health care interventions at the individual level, we did not include dynamic models, or infectious disease models, which focus on describing epidemics rather than on evaluating strategies for decisionmaking purposes. We also excluded papers that reviewed current evidence around a topic, which may include pertinent decision analysis models, but did not use a model explicitly.

### Screening and Data Abstraction

#### Model Definition

To ensure a broad look at the use of models in the literature, we defined a decision model as a mathematical structure developed to synthesize two or more sources of evidence, used to project out the health outcomes associated with alternative policies. This model definition is broader than what was applied to determine eligibility for the database discussed in the Potential Modeling Resources section of this report. Again, the purpose here was to generate a broad sense of the state of the literature.

#### Abstract Review

References generated from the search string were imported to Refworks for screening. Two reviewers screened all reference titles and abstracts for inclusion or exclusion. Conflicts were reconciled by a third reviewer through consensus. Included references were retained for abstracting. For excluded abstracts, the reason for exclusion was noted. Each abstract retained was reviewed independently by two readers. The reviewers abstracted the following information: title, journal, country of primary author, type of intervention, class of intervention, target disease, country of the target population, age group of the target population (children, adult, elderly), and the type of health outcome reported. The reviewers met to compare abstraction results; conflicts were reconciled through consensus, using a third reviewer if necessary.

#### Intervention Classification

The modeling analyses were classified according to the type of interventions that were evaluated: prevention, screening, diagnosis, and treatment.

Models were classified as “prevention” if the model studied an intervention aimed at a population with no symptoms with the express intent to prevent a certain disease. This most often includes models to evaluate the effectiveness of vaccinations, but also included pharmacological and other types of interventions, e.g., bed nets for malaria prevention.

Models were classified as “screening” if the intervention pertained to patients with no specific symptoms or diseases but was a method to determine a certain affliction from a general population. There were some caveats allowed in this definition in cases where a higher-risk population could be identified by factors other than signs and symptoms of a disease or condition. For example, we would categorize colonoscopy screening every 5 years among individuals who have had a polypectomy in the past as screening. Although this group is at higher risk of having colorectal cancer or an adenomatous polyp than the general population, members do not have signs and symptoms of disease at the time of the colonoscopy. (Note that in practice, this is referred to as surveillance and not screening.) Screening also includes those models that examine strategies of screening versus treatment of certain disease.

The “diagnosis” categorization includes models that target a population with a set of signs and symptoms related to a disease. Diagnostic interventions include the use of a diagnostic test to gather more information about the disease status of the patient and to target subsequent treatment or further testing based on the test results. This category includes lab testing, radiological test, and genetic tests.

Models were given the categorization of “treatment” if the model examined a certain intervention to be used on patients who had a specific disease. This can include pharmacological interventions, procedural interventions (surgery, noninvasive device), or organizational interventions, such as stroke unit care. Treatment can also include strategies aimed at preventing complications in the normal course of treatment for disease, such as using a certain kind of surgical instrument to avoid infections when treating a patient.

#### Disease Classification

The articles were also classified according to the diseases targeted with the interventions. These diseases represent either the disease that the target population already had (in the case of treatment), the disease that the target population might have (in the case of screening or diagnostic interventions), or the disease that the intervention is aimed at preventing, (in the case of prevention.) Table 4 shows the disease categories that we used.

Table 4 Disease categories

Disease Type | Comments
Cancer | Excludes benign tumors, polyps.
Cardiovascular diseases | Includes heart and vascular disease, stroke, embolisms, aneurysms.
Bones/joints
Lung diseases | Includes COPD, pneumonia, pneumococcal TB, asthma. Excludes lung cancer.
Hepatitis/liver diseases | Excludes cancers of the liver.
Mental disorders | Includes MDD, dementia, Alzheimer's, ADHD.
Kidney diseases | Includes CKD, renal hypertension, kidney injury. Excludes renal cancers.
Pregnancy/infertility/birth defects
Rotavirus
Gastrointestinal | Excludes gastrointestinal cancers.
Vision/eyes
Diabetes | Includes type I and type II.
HIV/AIDS
Influenza
MRSA/nosocomial infection
Multiple diseases/conditions
Smoking/smoking related illnesses | Includes only studies with self-defined “smoking related disease” groupings; may include lung cancer.
Multiple sclerosis
Hearing/ears
Other | Diseases or conditions not covered above.

COPD = chronic obstructive pulmonary disease; TB = tuberculosis; MDD = major depressive disorder; ADHD – attention deficit hyperactivity disorder; CKD = chronic kidney disease; HIV/AIDS = human immunodeficiency virus/acquired immune deficiency syndrome; MRSA = methicillin-resistant Staphylococcus aureus.

### Summary Statistics

For the 5-year time period, we calculated the distributions of the home country of primary author, the journal, type of intervention, disease categories, the target population, and outcomes measures.

## Results

We present an overview of the use of decision-analytic models in the medical literature over the past 5 years. We identified 1,773 articles published in 2005–2009 that included the use of a decision model to compare the clinical outcomes associated with two or more strategies and excluded an additional 1,075 articles. Of the 1,075 articles excluded, the majority (56 percent) were deemed to be outside the scope of the review because they did not involve the comparison of two or more health care interventions. Other reasons for not including articles are shown in Table 5.

Table 5 Reason for rejection (2005–2009)

Reason | Number of Articles | Percent
Outside scope of review | 601 | 56%
Review | 171 | 16%
Statistical analysis | 163 | 15%
No abstract | 65 | 6%
Costs only | 62 | 6%
Decision aid | 11 | 1%
Comment letter | 2 | <1%
Total excluded articles | 1,075

The home country of the primary author was the United States for 42 percent articles, and this was fairly consistent across years. The second most common home country of the primary author was the United Kingdom (16 percent), which was also consistent across this timeframe. Table 6 shows the distribution of the home country of the primary author of the 2005–2009 modeling articles.

Table 6 Home country of primary author (2005–2009)

Country | Number of Included Articles | Percent
United States | 741 | 42%
United Kingdom | 291 | 16%
Canada | 133 | 8%
Netherlands | 98 | 6%
Australia | 65 | 4%
Sweden | 59 | 3%
Japan | 40 | 2%
Switzerland | 39 | 2%
Germany | 37 | 2%
France | 33 | 2%
Belgium | 32 | 2%
Spain | 30 | 2%
Italy | 24 | 1%
Taiwan | 12 | <1%
Denmark | 11 | <1%
China | 10 | <1%
Thailand | 10 | <1%
Greece | 8 | <1%
Korea | 7 | <1%
Finland | 7 | <1%
Austria | 7 | <1%
Ireland | 7 | <1%
Israel | 7 | <1%
Brazil | 6 | <1%
Not specified | 5 | <1%
Argentina | 4 | <1%
Norway | 4 | <1%
Columbia | 4 | <1%
Slovenia | 3 | <1%
South Africa | 3 | <1%
New Zealand | 3 | <1%
Kenya | 2 | <1%
Paraguay | 2 | <1%
Portugal | 2 | <1%
Hong Kong | 2 | <1%
Chile | 2 | <1%
Turkey | 2 | <1%
Other^*^ (1 article) | 17 | <1%
Total included articles | 1,773

* India, Haiti, Bulgaria, Estonia, Russia, Hungary, Saudi Arabia, Egypt, Sendai, Ecuador, Republic of Congo, Mexico, Serbia and Montenegro, Ghent, Jordan, Indonesia.

Health Technology Assessment published the most articles (5 percent) in 2005–2009, followed by Pharmacoeconomics (4 percent). Table 7 shows the distribution of articles by journal name. Table 8 shows the type of interventions modeled in the 2005–2009 modeling papers. The majority of the intervention types were treatment, representing 70 percent of the total articles. Among the articles that targeted a diseased population, 46 percent of the interventions were pharmaceutical interventions, and 14 percent of them evaluated procedural interventions. The second most common intervention type (12 percent) was prevention, most of which pertained to the evaluation of vaccinations. Screening strategies were evaluated in 12 percent of the articles and diagnostic interventions were evaluated in 6 percent of the 2005–2009 articles. These findings were consistent across years. (Data not shown.)

Table 7 Journals represented with more than seven articles (2005–2009)

Journal Name | Number of Articles | Percent
Health Technology Assessment | 95 | 5%
Pharmacoeconomics | 78 | 4%
Current Medical Research & Opinion | 61 | 3%
Value in Health | 50 | 3%
Vaccine | 49 | 3%
International Journal of Technology Assessment in Health Care | 40 | 2%
Clinical Therapeutics | 31 | 2%
European Journal of Health Economics | 22 | 1%
Medical Decision Making | 21 | 1%
Annals of Internal Medicine | 20 | 1%
Cancer | 20 | 1%
Pediatrics | 19 | 1%
Alimentary Pharmacology & Therapeutics | 18 | 1%
Journal of Clinical Oncology | 17 | <1%
British Medical Journal (BMJ) | 16 | <1%
Osteoporosis International | 16 | <1%
Breast Cancer Research & Treatment | 15 | <1%
Obstetrics & Gynecology | 15 | <1%
Archives of Internal Medicine | 14 | <1%
JAIDS: Journal of Acquired Immune Deficiency Syndromes | 14 | <1%
Gynecologic Oncology | 13 | <1%
Sexually Transmitted Diseases | 12 | <1%
Clinical Gastroenterology & Hepatology | 12 | <1%
American Journal of Obstetrics & Gynecology | 12 | <1%
Clinical Drug Investigation | 11 | <1%
Radiology | 11 | <1%
Journal of Bone & Joint Surgery – American Volume | 10 | <1%
Rheumatology | 10 | <1%
Hepatology | 9 | <1%
AIDS | 9 | <1%
Health Policy | 9 | <1%
Gastrointestinal Endoscopy | 8 | <1%
American Journal of Preventive Medicine | 8 | <1%
Annals of Oncology | 8 | <1%
All other | 1,000 | 56%
Total included articles | 1,773

Table 8 Type of intervention modeled (2005–2009)

Intervention Type | Number of Articles | Percent
Treatment | 1,240 | 70%
Pharmacy | 809 | 46%
Procedure | 248 | 14%
Other | 168 | 9%
Multiple | 3 | <1%
N/A | 2 | <1%
Vaccination | 1 | <1%
Prevention | 209 | 12%
Vaccination | 131 | 7%
Pharmacy | 29 | 2%
Other | 45 | 3%
Multiple | 1 | <1%
Procedure | 2 | <1%
Screening | 219 | 12%
Diagnostic | 104 | 6%
Multiple | 1 | <1%
Total included articles | 1,773

N/A = not applicable

Table 9 shows the classes of disease types that were the focus of the 2005–2009 articles. The most common disease type evaluated was cancer (20 percent of the articles), followed by cardiovascular diseases (14 percent of the articles), and this was consistent across the 5 years (data not shown).

Table 9 Diseases addressed by models (2005–2009)

Disease Group | Number of Articles | Percent
Cancer | 348 | 20%
Cardiovascular diseases | 256 | 14%
Bones/joints | 113 | 6%
Lung diseases | 91 | 5%
Hepatitis/liver diseases | 82 | 5%
HIV/AIDS | 73 | 4%
Diabetes | 69 | 4%
Mental | 69 | 4%
Gastrointestinal | 69 | 4%
Pregnancy/infertility/birth defects | 55 | 3%
Kidney diseases | 45 | 3%
Multiple diseases/conditions | 45 | 3%
Influenza | 37 | 2%
Vision/eyes | 32 | 2%
Smoking/smoking related diseases | 29 | 2%
Rotavirus | 20 | 2%
MRSA/nosocomial | 16 | <1%
Multiple sclerosis | 9 | <1%
Hearing/ears | 9 | <1%
STDs (other than HIV/AIDS) | 7 | <1%
All other | 299 | 17%
Total Included articles | 1,773

HIV/AIDS = human immunodeficiency virus/acquired immune deficiency syndrome; MRSA = methicillin-resistant Staphylococcus aureus; STDs = sexually transmitted diseases.

Table 10 shows the age (in broad categories) and sex of the target populations for those modeling articles that specified age and sex in the abstracts for 2005–2009. Approximately 10 percent of the 1,773 articles specifically stated that the focus of the analysis was on a pediatric population, while 6 percent of the stated a focus on an elderly only population and 15 percent with a stated focus on women only.

Table 10 Target populations (2005–2009)

Target Age Group | Target sex
Target Age Group | Both sexes | Female | Male | Not specified | Total Included Articles | Percent
Adults | 395 | 162 | 50 | 31 | 638 | 36%
Children | 143 | 21 | 2 | 10 | 176 | 10%
Adults and elderly | 185 | 58 | 13 | 11 | 267 | 15%
Elderly | 62 | 17 | 16 | 8 | 103 | 6%
All ages | 108 | - | - | - | 108 | 6%
Children and adults | 26 | 11 | - | 1 | 38 | 2%
Not specified | 140 | 21 | 2 | 280 | 443 | 25%
Total included articles | 1,059 | 290 | 83 | 341 | 1,773
Percent | 60% | 15% | 5% | 19%

Table 11 shows the primary outcome measures reported in the 2005–2009 modeling articles. The majority of the articles reported adjusted life years as an outcome (62 percent). Other outcomes reported included life years, survival, and cases detected.

Table 11 Primary outcome measures (2005–2009)

Measure | Number of Articles | Percent
Adjusted life years | 1,085 | 62%
QALY | 1,027
DALY | 57
VALY (visual acuity) | 1
Life years | 144 | 8%
Mortality/survival | 80 | 5%
Cases/cases detected/cases diagnosed | 63 | 4%
Sensitivity/specificity | 27 | 2%
Live births | 8 | <1%
Utility | 7 | <1%
Incidence/prevalence | 5 | <1%
All others (including no primary measure abstracted) | 354 | 20%
Total included articles | 1,773

QALY = quality-adjusted life year; DALY = disability-adjusted life year; VALY = visual acuity-adjusted life year.

Table 12 shows the intervention types by disease category. While 22 percent of the overall articles focus on cancer, 36 percent of the screening articles focus on cancer. Some diseases are associated almost exclusively with treatment-related interventions (>90 percent of disease-specific articles are related to treatment). These include mental disease, kidney diseases, and multiple sclerosis. The diseases that were more associated with prevention interventions (>25 percent of the disease-specific articles) were lung diseases, influenza, and rotavirus. Most of the interventions pertaining to gastrointestinal disease were related to diagnostics.

Table 12 Intervention types modeled by associated disease (2005–2009)

Disease Group | Intervention type
Disease Group | Treatment | Prevention | Screening | Diagnostic | Multiple | Total Included Articles | Percent
Cancer | 211 | 32 | 72 | 33 | - | 348 | 20%
Cardiovascular diseases | 216 | 8 | 14 | 18 | 1 | 256 | 14%
Bones/joints | 92 | 6 | 11 | 4 | - | 69 | 6%
Hepatitis/liver diseases | 52 | 17 | 10 | 3 | - | 82 | 5%
Lung diseases | 50 | 23 | 8 | 10 | - | 91 | 5%
Diabetes | 59 | 3 | 7 | - | - | 69 | 4%
HIV/AIDS | 46 | 10 | 16 | 1 | - | 73 | 4%
Mental diseases | 66 | - | 2 | 1 | - | 69 | 4%
Kidney diseases | 44 | - | - | 1 | - | 45 | 3%
Gastrointestinal | 53 | 3 | 3 | 10 | - | 55 | 3%
Pregnancy/infertility/birth defects | 34 | 6 | 11 | 4 | - | 55 | 3%
Vision/eyes | 21 | - | 10 | 1 | - | 32 | 2%
Influenza | 10 | 26 | 1 | - | - | 37 | 2%
Rotavirus | - | 20 | - | - | - | 20 | 2%
Smoking/smoking related diseases | 20 | 8 | 1 | - | - | 29 | 2%
Multiple diseases | 32 | 7 | 4 | 2 | - | 45 | 3%
STDs (other than HIV/AIDS) | - | - | 7 | - | - | 7 | <1%
MRSA/nosocomial infection | 11 | 2 | 3 | - | - | 16 | <1%
Multiple sclerosis | 9 | - | - | - | - | 9 | <1%
Hearing/ears | 6 | 1 | 2 | - | - | 9 | <1%
All other diseases | 204 | 32 | 72 | 33 | - | 299 | 17%
Total included articles | 1,240 | 209 | 219 | 104 | 1 | 1,773
Percent | 68% | 14% | 12% | 5% | <1%

HIV/AIDS = human immunodeficiency virus/acquired immune deficiency syndrome; STDs = sexually transmitted diseases; MRSA = methicillin-resistant Staphylococcus aureus

## Summary

We provide a bird's eye view of the articles that used a decision model to incorporate data from multiple sources to evaluate two or more strategies for decisionmaking purposes. Over a 5-year period, we identified more than 1,700 articles in several disease areas and intervention types published in journals listed in Medline. It is possible that we missed some studies as we did not search other databases (e.g., EconLit, Heath Economic Evaluations Database). The diseases areas and interventions types are fairly representative of those evaluated by systematic reviews. The majority of the decision analysis papers evaluated an intervention aimed at individuals with existing disease, and surprisingly few were focused on diagnostic-related strategies.

Overall, 42 percent of the articles came from the United States, though over 45 countries were represented (home country of primary author). A wide variety of journals publish decision analysis papers. The journal that published the greatest number of articles, Health Technology Assessment, only represents 5 percent of the total papers. However, it is not surprising that Health Technology Assessment is a leading journal for publishing models because they publish peer-reviewed reports from the Health Technology Assessment program in the United Kingdom.

The most common disease type evaluated was cancer (20 percent of the articles), followed by cardiovascular diseases (14 percent of the articles). The majority of the target populations were adults, with approximately 10 percent of the 1,773 articles with a focus on a pediatric population, and 6 percent with a focus on an elderly population. In addition, 15 percent of the articles were targeted towards women only. The majority of the articles reported adjusted life years as an outcome (62 percent), the majority of which used quality-adjusted life years as the outcome.

The search algorithm we developed for this analysis could be useful in the future to identify studies that use a decision model within a disease area. (See Potential Modeling Resources.) We found that the search algorithm has a reasonable yield (61 percent) in terms of the percent of papers subsequently found to include a decision model. However, we are not certain how many decision models we have missed.

An overview of the decision analysis field, as detailed by this analysis of the decision modeling literature, provides a first step in the development of a framework for using models with systematic reviews. While there are a relatively large number of papers that have used the methods of decision analysis in the past three years, they tend to be published in journals whose audience is modelers, or in somewhat lower-tiered clinical journals. There are exceptions to this, of course, but one goal for the field of decision analysis is to reach a broader audience through publication in high-impact clinical journals. Development of a model alongside a systematic review may help move the field in this direction, as there would be opportunities to publish in the Annals of Internal Medicine. Also, the connection to a well-done systematic review and formal decisionmaking process will likely add to the credibility and understanding of the use of decision models for policymaking.