# Executive Summary

## Overview of Report

The overarching goal of our report is to provide guidance to determine when incorporating a decision-analytic model alongside a systemic review would be of added value for decisionmaking purposes. The purpose of systematic reviews is to synthesize the current scientific literature on a particular topic in the form of evidence reports and technology assessments to assist public and private organizations in developing strategies that improve the quality of health care and decisionmaking. However, there is often not enough evidence to fully address the questions that are relevant for decisionmakers. Or, there may be enough evidence on several components to the decision (e.g., diagnostic test characteristics, test risks, risk and effectiveness of treating disease), but no studies that evaluate the relevant clinical strategies that incorporate all of these components. In this example, the most relevant question for decisionmaking purposes is to address the comparison of alternative test-and-treat strategies, which synthesizes all of these data elements. Our framework is informed by two sets of interviews and a focus group discussion; literature reviews to summarize best modeling practices and to profile the modeling literature; and an exploration of the feasibility of the developing of a database of published models.

We present our findings in six chapters. Decision and Simulation Modeling Alongside Systematic Reviews provides an overview of models, and describes the differences and synergies between systematic reviews and decision analysis. In Overview of Decision Models Used in Research, we provide a “scan” of the medical literature over the past five years in terms of the use of models in studies that compare intervention strategies using multiple sources of data. Use of Modeling in Systematic Reviews: The EPC Perspective documents the extent to which Evidence-based Practice Centers (EPCs) have incorporated models to data, and presents results from key informant interviews with EPC members. We present a framework for deciding when a decision model can inform decisionmaking alongside a systematic review in Suggested Framework for Deciding When a Modeling Effort Should be Added to a Systematic Review. Potential Modeling Resources explores several possible approaches to use when undertaking a modeling effort and discusses some of the challenges. Lastly, Best Practices for Decision and Simulation Modeling reviews the literature on best practices for modeling, supplemented by a focus group discussion with modeling experts, and lessons learned about the process of conducting a modeling exercise alongside a systematic review using recent experience with the U.S. Preventive Services Task Force (USPSTF).

## Decision and Simulation Modeling Alongside Systematic Reviews

Objective: To clarify the role of decision analysis and decision-analytic models in health care, specifically within the context of the current emphasis on evidence-based medicine and the proliferation of systematic and comparative effectiveness reviews.

This chapter sets the stage for the remainder of the report. We provide the historical context for the field of medical decisionmaking, documenting the growth of this relatively new discipline and noting the persistent concerns raised about its value in practice. Decision analysis is a systematic, quantitative, and transparent approach to making decisions under uncertainty. While the methods of decision analysis have been applied to medicine for over 40 years, their use has only had modest impact on real-world decisionmaking.

The role of systematic reviews is to inform decisionmakers and policymakers about the current evidence pertaining to a clinical question that is aimed at improving the quality of health care and the lives of patients. Often situations arise where there is not enough evidence to fully address the clinical question, or where there are multiple sources of evidence available. In the absence of a systematic and formal approach to assist the decisionmaker(s) in the processing of the often disparate and complex evidence, the processing occurs in a more informal way, which may involve implicit value judgments and cognitive biases.

Decision-analytic models are mathematical structures that can be used to simulate the health outcomes of individual patients or populations under a variety of scenarios. They represent the core methodology of clinical decision analysis. Decision models can be a powerful tool for assessing public health and clinical policies for improving quality of health care and decisionmaking. Models can be used to: (1) project out beyond the time horizon of intervention studies, (2) extrapolate to other population subgroups not directly observed within a study, (3) incorporate data from multiple sources (e.g., clinical and health-related quality-of-life endpoints), (4) evaluate relevant comparators that have not been included in trials, and (5) project intermediate outcome measures (e.g., cases of cancer) used in trials to long-term outcomes, such as quality-adjusted life expectancy. One area where models may provide added value is alongside systematic reviews by adding a formal structure that could be informed by the evidence. The development of a decision model requires the analyst to synthesize all of the relevant literature that pertains to the question, including parameters for the natural history of (or risk of) a disease, effectiveness and risks of alternative interventions, and health-related quality of life. Thus, a modeling endeavor often relies on much of the same information provided by a systematic review, but it typically needs to be supplemented by clinically reasonable assumptions where data may be limited or nonexistent.

If done in a transparent manner, the methods of decision analysis provide a systematic and explicit way to examine a decision process and are an obvious companion for systematic reviews when there are limitations in the evidence base or multiple sources of evidence that require synthesis. Several types of decision models are appropriate for different types of clinical questions. However, they are all used for the same purpose: to assist in decisionmaking under uncertainty when a decision must be made.

Key Findings

- Decision models are mathematical structures that can synthesize multiple sources of evidence in a logical framework and project additional clinical outcomes that could be of value for decisionmaking.
- Although decision models have been used in medicine for over 40 years, their impact on decisionmaking has been modest.
- Systematic reviews are more commonly used to inform decisionmaking for a range of different clinical questions.
- The methods of decision analysis provide a systematic and explicit way to examine a decision process and are an obvious companion for systematic reviews when there are limitations in the evidence base or multiple sources of evidence that require synthesis.

## Overview of Decision Models Used in Research

Objective: To profile the use of decision models in the published medical literature over the past 5 years. Decision modeling studies are defined as those that compare clinical outcomes associated with two or more strategies and incorporate data from multiple sources.

In this chapter, we present the results of a systematic review of the medical literature and the grey literature that documents and synthesizes all articles that used a decision-analytic model, including relevant cost-effectiveness analyses, conducted during 2005–2009. While there have been studies that document the use of cost effectiveness analyses or cost utility analyses, there has not been a comprehensive documentation of the use of decision analysis models in the literature. The purpose of this review was to get an overview of how prevalent the use of decision-analytic models is in the medical literature; to learn whether there are any patterns in their use, including country of origin; and to document what types of questions are typically addressed with a decision model.

We identified 1,773 articles in 2005–2009 that included the use of a decision model to compare the clinical outcomes associated with two or more strategies. The home country of the primary author was the United States for 42 percent of the articles. This was fairly consistent across years. The second most common home country of the primary author was the United Kingdom (16 percent), which was also consistent across this time frame. The journal Health Technology Assessment published the most articles (5 percent) in 2007–2009, followed by Pharmacoeconomics (4 percent).

The majority of the interventions modeled were treatment-related, representing 70 percent of the total articles. The second most common intervention type (12 percent) was prevention. These findings were consistent across the 5 years. The most common disease category evaluated was cancer (20 percent of the articles), followed by cardiovascular diseases (14 percent of the articles), and this was consistent across the 5 years. Approximately 11 percent of the articles specifically stated that the focus of the analysis was on a pediatric population, while 5 percent stated a focus on the elderly, and 15 percent had a stated focus on women only. The majority of the articles reported adjusted life years as an outcome (62 percent), most often quality adjusted life years. Other outcomes reported included life years, survival, and cases detected. While 20 percent of the overall articles focused on cancer, 33 percent of the screening articles focused on cancer. Some diseases were associated almost exclusively with treatment-related interventions (>90 percent of disease-specific articles related to treatment). These included mental diseases, kidney diseases, and multiple sclerosis. The diseases that were more commonly associated with prevention interventions (>25 percent of the disease specific articles) were lung diseases, influenza, and rotavirus. Most of the interventions pertaining to gastrointestinal diseases were related to diagnostics.

Key Findings

- Approximately 350 articles are published annually that use a decision model to compare alternative strategies.
- The majority of the interventions examined pertain to treatment, representing 70 percent of the total articles.
- The most common disease type evaluated is cancer (20 percent of the articles), followed by cardiovascular diseases (14 percent of the articles).

## Use of Modeling in Systematic Reviews: The EPC Perspective

Objective: To review past EPC reports that have incorporated models and outline the specific reasons for incorporating models, the outcomes examined, and model contributions to the conclusions of the report. To complement the review of EPC reports, we also interviewed relevant EPC members about lessons learned from incorporating decision models in EPC reports.

This chapter documents the work done to date by EPCs to incorporate a decision model as part of a systematic review. We identified 11 EPC reports that used decision models. Only four used models as the prime methodology to answer key questions; the remaining seven used models to augment systematic review results. Reasons for incorporating models into the evidence reports include: (1) linking intermediate outcomes to clinical or patient-centered outcomes, (2) simulating head-to-head comparisons of interventions that were otherwise unavailable in the literature, (3) examining the cost-effectiveness of an intervention, and (4) modeling a novel hypothesis for disease progression to determine the impact on screening.

We developed a semistructured interview guide with four main themes: (1) what types of questions require a model, (2) what model outputs deliver the greatest utility to stakeholders, (3) what is the working definition of a model, and (4) how does one determine the quality of a model. We conducted phone interviews with EPC members from all EPCs. Interviewees with any degree of familiarity with models, whether firsthand or secondhand, tended to respond more similarly than those with no experience. Those interviewees with modeling experience unanimously held positive attitudes toward modeling with respect to its benefit in augmenting the evidence from systematic reviews. They stated that models are well suited to address gaps in the literature and to synthesize literature from differing sources and contexts into a single representation of the empirical evidence. The interviewees identified the lack of defined standards and methods as a major problem in the evaluation of models and hoped that this initiative would bring about some initial draft evaluation standards. A frequent issue mentioned was the ability to determine the opportunity or need for a model and/or simulation before the project has started, specifically before the question refinement phase has been completed and before an early stage literature review has been conducted. Lastly, all interviewees reported the desire for training resources.

Key Findings

- Eleven systematic reviews conducted by EPCs have incorporated a decision model.
- Interviewees with any degree of familiarity with models, whether first or second hand, tended to respond more similarly than those with no experience.
- Interviewees with modeling experience unanimously held positive attitudes towards modeling alongside systematic reviews.
- Interviewees stated that models are well-suited to address gaps in the literature and to synthesize literature from differing sources and contexts into a single representation of the empirical evidence.
- The interviewees identified the lack of defined standards and methods as a major problem in the evaluation of models and hoped that this initiative would bring about some initial draft evaluation standards.

## Suggested Framework for Deciding When a Modeling Effort Should Be Added to a Systematic Review

Objective: To develop a framework for deciding when a decision model can inform decisionmaking alongside a systematic review of the evidence.

This chapter lays out a suggested framework for deciding when a decision model could be of added value to a systematic review. The purpose of systematic reviews is to synthesize the current scientific literature on a particular topic in the form of evidence reports and technology assessments to assist public and private organizations in developing strategies that improve quality of health care and decisionmaking. The addition of a decision analysis alongside a systematic review, as a separate yet integrated endeavor, would provide a tool for the decisionmaker that projects relevant health outcomes for all of the available options for several population subgroups. One of the most likely areas where a model could add value to a systematic review is for comparative effectiveness reviews.

The use of a modeling study should be supported and valued at the start by the relevant stakeholder(s). This may require that the stakeholder(s) be educated on what decision models are, how they have been used in practice, and their value. The timing of a modeling project in connection with a systematic review is important. One approach would be to have the report from the modeling study coincide with that of the systematic review. However, the results from the systematic review typically will be required to conduct the final modeling analysis. Thus, the addition of a decision model could delay the overall project. Another concern is the ability to determine the opportunity or need for a model before the project has started or before the question refinement phase has been completed. The proposal process could be augmented to include a more collaborative question refinement prior to proposal submissions, which would involve a relatively quick review of the literature to determine if there were aspects of the disease and interventions that were suitable for modeling.

Although decision models provide synergies with systematic reviews, the skills required to develop and analyze decision models are not typically well represented by groups that conduct systematic reviews. Because decision modeling requires a different skill set, it would be limiting to require that modeling work be done by the same team of researchers conducting a systematic review. Modeling is a multidisciplinary field that requires a nexus of experts in order to conduct credible modeling exercises on a wide variety of topics in timelines typical of a systematic review.

The several checklists available for determining best practices for evaluating decision models provide a minimum requirement for models. We propose that a checklist be used more to guide the documentation of a model and less to help distinguish “good” models from “bad” models. Again, if we focus on using models to assist the decisionmaker, a good model is one that includes inputs and outputs that are relevant to the decisionmaker and is ultimately useful and used by the decisionmaker. Model outcomes should always include those deemed relevant by the decisionmaker. However, we also recommend that a standard set of model outputs be developed to help with comparisons across models and aid in the acceptance of models over time. We recommend that quality adjusted life years (QALYs) be included as standard output, even though this may not be the most useful to a decisionmaker. In addition, life years (LYs) should also be included, as well as output that adds insight into the differences between the QALYs and LYs. For example, model output on the average amount of time spent in different health states could be provided to provide insight into QALYs. That is, , average QALYs are equal to the average time spent in each health state multiplied by the quality-of-life weight assigned to each state.

Findings from our interviews highlight the need for training users of decision models to educate them about the value, uses, and misconceptions of modeling. Opportunities for educating potential users of decision models could be created by incorporating a mechanism to conduct modeling alongside systematic reviews. Specifically, as a result of the interactive nature of the proposed framework, the modeling teams would be required to communicate the value of the decision modeling approach in a way that appeals to and is understood by the nonmodeling community. Part of the challenge to using decision analysis for real-world decisionmaking has been in communicating their value to policymakers and other nondecision analysts.

Key Findings

- The use of a modeling study should be supported and valued at the start by the relevant stakeholder(s), which may require that the stakeholder(s) be educated on what decision models are, how they are used in practice, and their value.
- Because decision modeling requires different skills than that needed to conduct systematic reviews, it would be limiting to require that modeling work be done by the same team of researchers conducting a systematic review.
- We propose that a checklist be used more to guide the documentation of a model and less to help distinguish “good” models from “bad” models.
- Model outcomes should always include those deemed relevant by the decisionmaker. However, we also recommend that a standard set of model output be developed to help with comparisons across models and aid in the acceptance of models over time.

## Potential Modeling Resources

Objective: To explore several possible approaches to take when undertaking a modeling effort and discuss some of the challenges.

In this chapter, we compared three basic approaches for incorporating decision modeling alongside a systematic review: (1) a synthesis of the results of previous modeling studies, (2) modification of an existing model(s) so that it can be used to complement a systematic review, and (3) request the development of a de novo model. The first approach would provide a good first step to understanding the modeling issues pertaining to a disease and treatment area, but has several limitations in that it may not fit the question precisely, and it does not allow for input from the stakeholders. The second approach would require that modelers be willing to make changes to their models that are consistent with the values of the stakeholder, which may involve significant reprogramming in some cases. A key advantage to the third approach over using existing models is that it would limit any influence from prior modeling assumptions and would allow perhaps more unbiased input from stakeholders and the systematic reviews. This approach would be the most time consuming and costly, and may not be feasible for disease areas that require a fairly sophisticated modeling approach, such as cancer screening strategies.

To assist in identifying existing modelers, we explored the feasibility and potential value of a modeling database that includes some basic details about the existing models in the literature. There is potential value to developing a searchable database of models. However, more research is required to determine the most useful data fields and the best process of development and updating.

Key Findings

- There are three basic approaches that could be used once a decision has been made to use a decision model alongside a systematic review: (1) a synthesis of the results of previous modeling studies, (2) identify modeling groups that have an existing model that would be relevant for the particular systematic review, and (3) request the development of a de novo model.
- There is potential value to developing a searchable database of models. However, more research is required to determine the most useful data fields and the best process of development and updating.

## Best Practices for Decision and Simulation Modeling

Objective: To review and elicit best practices and recommendations for developing, validating, and using decision-analytic models in general as well as in the context of systematic reviews to inform decisionmaking of stakeholders such as the USPSTF.

This chapter focuses on best practices for decision-analytic models. We took a multipronged approach to gather information on best practices and recommendations for decision models. To identify existing recommendations for best practices in decision and simulation modeling we conducted a literature search. We identified 39 articles that provided guidance on key elements of what constitutes a good decision or simulation model. Of those 39 papers, 7 discuss good modeling practices; 4 discuss the roles, uses, or value of modeling in general; 20 focus on specific aspects of modeling; 3 propose comprehensive guidelines for modeling in a specific clinical domain; and 5 review and compare models in specific clinical areas. A compilation of all elements led to a structured list of 24 dimensions of model quality organized along four dimensions: structure, data, consistency/validation, and communication.

To complement our search of the current literature, we conducted a focus group of expert modelers to further discuss, characterize, and qualify best practices in decision and simulation modeling in general. The experts framed the discussion of modeling within the context of a decisionmaking framework, reiterated the results from the literature review regarding quality of models, further developed the need for interaction between the model and the decisionmaker(s) the model is intended to inform, and further developed the importance of model and model results communication.

To profile potential best practices of coordinating the simultaneous or sequential systematic review and modeling exercise, we interviewed breast, cervical, and colorectal modelers as well as USPSTF members about lessons learned from conducting decision and simulation models alongside systematic reviews to inform USPSTF recommendations. Three main themes emerged from these interviews: (1) communication and presentation of model results, (2) modeling literacy, and (3) recommendations for future projects. Despite the variability in how the modeling efforts were conducted across the three cancer projects, there was a high degree of consistency among interviewees regarding communication and modeling literacy. Interviewees stress difficulty in communicating models and results as a critical issue that needs to be addressed to improve success and acceptance of models. Interviewees also cited the need for some degree of modeling literacy among decisionmakers to increase understanding, acceptance, and use of models. There were differences among the respondents regarding recommendations for future projects. Overall, interviewees formulated a variety of recommendations along five basic categories: (1) goals and objectives for the project, (2) outputs and results, (3) USPSTF interactions with modelers and/or reviewers, (4) project lead on the USPSTF, and (5) interactions between modeling and systematic review teams.

Key Findings

- A compilation of all best practices for modeling articles led to a structured list of 24 dimensions of model quality organized along four dimensions: structure, data, consistency/validation, and communication.
- A focus group of modeling experts highlighted the need for interaction between the model and the decisionmaker(s) the model is intended to inform, and further developed the importance of model and model results communication.
- Interviews with USPSTF and modelers involved with the cancer screening recommendations revealed that the difficulty in communicating models and results is a critical issue that needs to be addressed to improve the success and acceptance of models.
- Interviewees also cited the need for some degree of modeling literacy among decisionmakers to increase understanding, acceptance, and use of models.