# Technical Expert Panel

- Mary Barton, M.D., M.P.P.
  U.S. Preventive Services Task Force
  Rockville MD
- Eric (Rocky) Feuer, Ph.D.
  National Cancer Institute
  Rockville MD
- Doug Owens, M.D., M.S.
  Stanford University
  Stanford, CA
- Diana Petitti, M.D., M.P.H.
  Arizona State University
  Tempe, AZ
- Steven Teutsch, M.D. M.P.H.
  Los Angeles County Public Health
  Los Angeles, CA
- Thomas Trikalinos, M.D., Ph.D.
  Tufts Medical Center
  Boston, MA