# Acknowledgments

We would like to thank Molly Jeffries and Jonah Pop for their assistance with data abstraction, and especially Marilyn Eells for her help with all aspects of editing, organizational skills, and professionalism. We also would like to thank the Technical Expert Panel members for their time and expert guidance.