# Decision and Simulation Modeling Alongside Systematic Reviews

## Overview

This chapter discusses the role of decision analysis and decision-analytic models in health care, specifically within the context of the current emphasis on evidence-based medicine and the proliferation of systematic reviews. Decision-analytic models are mathematical structures that can be used to simulate the health outcomes of individual patients or a population under a variety of scenarios; they represent the core methodology of clinical decision analysis. The goal of systematic reviews is to synthesize the current scientific literature on a particular topic in the form of evidence reports or technology assessments to assist public and private organizations in developing strategies that improve the quality of health care and decisionmaking. However, there is often not enough evidence to fully address the questions that are relevant to decisionmakers. Or, there may be enough evidence on several components of the decision (e.g., diagnostic test characteristics, test risks, risk and effectiveness of treating disease) but no studies that evaluate the relevant clinical strategies that incorporate all of these components in a manner that is most important for decisionmaking purposes, e.g., how does one test-and-treat strategy compare with an alternative test-and-treat strategy? Models may provide added value alongside systematic reviews by adding a formal structure, which can be informed by the evidence. The methods of decision analysis can provide a transparent, logical framework for structuring a decision process; decision analysis synthesizes all of the available evidence and projects outcomes that are relevant to the decisionmaker(s). One type of decision analysis is a cost-effectiveness analysis, which incorporates both the benefits and the costs of competing alternatives and explicitly considers a limited budget. Our report is focused on modeling more broadly and not on economic evaluations that use modeling to project costs and health benefits. Our framework would, in general, allow for inclusion of costs as an outcome.

Decision analysis is a quantitative discipline that can complement the fields of biostatistics and epidemiology. While the goals of biostatistics and epidemiology center on making inferences, or inferential statements about the truth, the goal of decision analysis is to make sound, rational, systematic decisions under conditions of uncertainty. Thus, decision analysis helps to understand the inherent tradeoffs that are present in complex decisions. It can identify those variables that most affect the decision and can help guide future research. In analyses that involve inference, a possible conclusion could be that there is not sufficient evidence to conclude that there is an effect and thus, no conclusive statements about the true effect can be made. In decision analysis, we start with the premise that a decision must be made and thus, there is no option to simply state that there isn't enough evidence to make the decision. A decision to not take action is indeed a decision, with potential consequences that are important to the decisionmaker and that can be quantified.

In the absence of a systematic and formal approach to assist decisionmakers in the processing of the (often disparate and complex) evidence, the processing occurs in a more informal way. It has been shown that individuals do not do a very good job processing multiple pieces of data in their heads. Tversky and Kahneman describe several biases and heuristics that may influence people when processing evidence informally, that is, in their heads.1 For example, a policymaker may place too much weight on the diagnostic performance of a test and not enough weight on the prior probability of disease. Rittenhouse outlined several challenges that occur with the direct use of efficacy studies for policymaking.2 Because many trials use a placebo comparison, it may not be an appropriate comparator for purposes of decisionmaking. In addition, because many patients in a trial receive protocol-driven care, the trial results may not be able to be generalized to a community setting (i.e., trials tend to have higher levels of adherence), and there may be other outcomes that are relevant to the decisionmaker that are not reported in a clinical trial, such as late outcomes that are not adequately captured due to the time horizon of the trial. Lastly, trial populations typically only represent a subset of patients for whom a decision is relevant. Thus, decision analysis can reduce the cognitive biases of informal decisionmaking and can project outcomes that are the most relevant to the decisionmaker, informed by the best available evidence.

## Historical Overview of Decision Analysis

Decision theory has very early roots in mathematics, ethics, game theory, and economics.3 In 1944, von Neumann and Morgenstern proposed the mathematical foundations for decision theory, which is based on four axioms of expected utility theory and which provide the framework for “rational” decisionmaking under uncertainty.4 They synthesize the concepts of probability and value using the framework of preferences for lotteries. Since the publication of this historic work there have been many applications of decision analysis in business, policy, economics, industrial engineering, and other fields. The first application to medicine occurred in 1959, when Ledley and Lusted published an article titled “Reasoning foundations of medical diagnostics: Symbolic logic, probability, and value theory aid our understanding of how physicians reason” in the journal Science.5 This landmark article focuses on diagnostics (i.e., how does a physician make a medical diagnosis?) and discusses three key concepts: logic, probability, and value. The authors discuss the importance of applying Bayes's formula to calculate the probability that a patient has a particular disease conditional on a set of signs and symptoms. (They use the terms “medical knowledge” to represent the concepts of sensitivity and specificity.) In addition, they apply the framework of expected utility theory to the choice of treatments, recognizing the probabilistic nature of the diagnosis (e.g., the diagnosis is Disease A, though there is a 70 percent chance of Disease A and a 30 percent chance of Disease B given the patient's signs and symptoms), and the relative effectiveness of alternative therapies. They propose that treatment decisions are based on the expected value of a valued outcome. In their examples, the outcomes were cure versus no cure in one and physician's assessment with regard to the pros and cons of treatment for each possible disease (ranging between −10 and 10) for the other. Drawing upon game theory, the authors note: “The process of choosing the best treatment can be described in the terminology of games. There are two players, the physician and nature. The physician is trying to determine the best strategy from his limited knowledge of nature. The … values … constitute the payoffs, what the physician will ‘win,’ and what nature will ‘lose’.”

The first publication of a medical application of decision analysis was Henschke and Flehinger's article titled “Decision Theory in Cancer Therapy,” published in 1967.^6^ The question addressed in that paper is whether or not prophylactic neck dissection should be done in the treatment of patients with cancer of the neck and head and no palpable metastasis to neck nodes. They note the high degree of risk associated with performing neck dissection among these patients and that the question “has plagued surgeons for more than 50 years and always produces spirited disagreement at medical meetings.”6 Neither this paper nor the examples in the Ledley and Lusted paper presents a formal decision tree, as these early examples were fairly simple and could be solved analytically. Much of the authors' discussion was focused on their experience with opposition to their approach. They faced concerns such as “human values are not suitable for quantitative analysis” or that the available evidence is limited. Other concerns noted were that these methods would not be applicable in practice (“It would not be possible to induce the cancer specialist to use a sophisticated mathematical procedure in his daily work.”) and the conclusions from decision theory only confirm what we already know and don't provide anything new.

In 1975, The New England Journal of Medicine focused an entire issue on articles and editorials pertaining to medical decisionmaking. Franz J. Ingelfinger, M.D., the editor at the time, stated in his editorial, “Analysis of the decision process is far from a new idea, but perhaps it is an idea whose time has come for those who deal with clinical medicine, whether as planners or practitioners.”7 By 1979, there was enough interest in the field of medical decisionmaking that a small group of researchers, mostly physicians, founded the Society for Medical Decision Making. The Society was formed “to promote the theory and practice of medical decisionmaking through scholarly activities, including research on and application of analytic methods to medical decisions affecting the care of individual patients, and to health policy decisions affecting the health of larger population.”

The first textbook in decision analysis applied to medicine, Clinical Decision Analysis, was published in 1980.^8^ In a foreword to the book, Howard Raiffa, Ph.D.—a prominent decision analyst at the Harvard Business School—writes:

“To me decision analysis is just the systematic articulation of common sense: any decent doctor reflects on alternatives, is aware of uncertainties, modifies judgments on the basis of accumulated evidence, balances risks of various kinds, considers the potential consequences of his or her diagnoses and treatments, and synthesizes all of this in making a reasoned decision that he or she decrees right from the patient. All that decision analysis is asking the doctor to do is to do this a lot more systematically and in such a way that others can see what is going on and can contribute to the decision process.”

This textbook presents the construct of the decision tree as the basic analytic tool for decision analysis. The construction of the decision tree helps the decisionmaker display the logical sequences involved in the decision process, with decision nodes representing cases where the decisionmaker has a choice and chance nodes representing cases where the outcome is ruled by chance and beyond the control of the decisionmaker. The use of Markov models for medical decisionmaking was introduced in 1983 in the form of a Markov chain that can be solved analytically.9 The primary difference between a Markov model and a decision tree is that the former models the risk of recurrent events over time in a straightforward fashion. This initial presentation of Markov chains formed the foundation for Markov processes,10 which allow for the incorporation of time-dependent transition probabilities. Another key development in training decision analysts occurred in 1980 with the establishment of the Division of Clinical Decision Making within the Department of Medicine at the New England Medical Center Hospital (currently the Division of Clinical Decision Making, Informatics and Telemedicine at Tufts Medical Center) by Drs. Stephen Pauker and Jerome Kassirer. The purpose of this division was to conduct research, teach, train physicians, and provide consultations for physicians who are uncertain about the optimal management strategy for an individual patient. These consultations included a literature review and formal decision analysis that explicitly weighed the risks and benefits of the available alternatives, and often resulted in publications. Two early DOS-based software packages designed to conduct decision analysis with trees and Markov processes (SMLTREE and DecisionMaker) were developed by fellows and faculty within this division during the 1980s.

Since 1980, there has been a steady increase in the number of decision analysis publications. Petitti reported an increase from approximately 20 decision analysis articles published in 1980 to approximately 250 articles published in 1997, based on a MEDLINE search.11 This is likely an underestimate, as many of the cost-effectiveness analysis publications (about 420 in 1997) would be based on a decision analysis model. During the 1990's the Patient Outcomes Research Teams (PORTs) were one of the first initiatives to introduce modeling into policy. These multidisciplinary centers focused on particular medical problems and generally had an evidence synthesis component, a decision analysis component, and a dissemination component. Since 1992, the use of models for policymaking has risen dramatically as an increasing number of countries use formal cost-effectiveness analysis of interventions for coverage decisions (e.g., National Institute of Health and Clinical Excellence in the United Kingdom). The methods of decision analysis have advanced significantly with availability of personal computers that allow for the use of advanced methods which rely on faster computing speed and several textbooks with a focus on decision-analytic methods. There has also been an increase in training programs that offer courses and degrees in decision analysis and in professional societies that focus on decision modeling related areas. Also, a commercial software package has come to market (TreeAge). However, the fundamental goal of decision analysis has not changed—to assist decisionmakers in making complex decisions under uncertainty by providing a systematic, transparent, and quantitative approach to decisionmaking.

## Taxonomy of Clinical Problems

In this section we present different types of clinical problems that are often addressed by systematic reviews, and for which decision-analytic models are used. We will introduce a taxonomy of clinical problems, based on one proposed by Kassirer et al. in a review of decision analyses prior to 1987.^12^Table 1 provides a summary of the different types of clinical problems. These categories may not be inclusive of all interventions, but they cover the vast majority.

Table 1 Summary of types of clinical problems

Type of Clinical Problem | Target Population | Intervention Goals
Prevention | Individuals without the disease or complication of interest; may be average risk or high risk. | Reduce the risk of disease or complication.
Screening/Prognostic | Individuals without the signs and symptoms of the disease of interest; may be average risk or high risk. | Detect underlying disease or marker for disease at an earlier and more treatable stage.
Diagnostics | Individuals with signs and symptoms of a disease. | Collect more information about the disease status to target treatment.
Treatment | Individuals with disease. | Reduce the risk of disease-related complications.

### Prevention

Prevention includes all interventions targeted towards individuals without a disease or complication, where the primary goal of the intervention is to reduce the risk of the disease or complication. The target population for interventions aimed at preventing disease would typically be a disease-free population, though they may represent those at high risk for the disease. The target population for interventions aimed at preventing complications is one with established disease, but the goal of the intervention is to prevent a complication and not treat the disease. An example of the latter would be predental antibiotic prophylaxis for patients with mitral-value prolapse.

One the most common prevention interventions is vaccination. Ideally, models that evaluate vaccinations against communicable diseases would utilize a dynamic model to capture the herd immunity effects. Interventions aimed at preventing noncommunicable diseases would typically involve modeling the risk of the disease over time. Evidence of the effectiveness of interventions that prevent disease typically involves long-term trials with large sample sizes with study populations that may not be generalizable to the population of disease-free individuals found in practice. Prevention trials can be costly compared to treatment trials and typically require a longer followup time to show a significant effect.

### Screening/Prognostic

Many people who do not show signs and symptoms of a disease actually have the disease, or may carry a marker for disease (e.g., genetic mutation, elevated cholesterol levels). The goal of screening is to identify those individuals who have underlying disease, or marker for disease, prior to the time when signs and symptoms appear. In general, screening is likely to be an effective approach if the following five criteria are met, as outlined by Russel:13 (1) the disease represents a significant burden on the population, (2) there is a reasonably long and/or detectable asymptomatic phase for the disease, (3) effective treatments are available for the condition, (4) treatment is more effective if delivered early, and (5) a test is available with good diagnostic performance characteristics. Often, screening does not involve a one-time screen; exceptions are newborn screening or genetic screening.

Cancer screening has been an active area for simulation modeling. Clinical trials that evaluate cancer screening strategies need to be long term with large sample sizes, yet they can never evaluate all of the possible strategies.

### Diagnostics

The use of diagnostic tests follows a classic example of the need for a formal approach to decisionmaking. The three basic types of decisions that one can make are: (1) take action, (2) do not take action, and (3) collect more information. This framework translates directly to the diagnostic testing situation. When a patient presents with suspected disease, he or she has a probability of having the disease that can be estimated based on the clinical and demographic characteristics of the patient. If the probability is high enough, the optimal decision will be to empirically treat the patient. If the probability is low enough, the optimal decision would be to not treat (and not test) the patient. However, there is a range of prior probabilities of disease (which can be quantified using the methods of decision analysis) for which collecting more information in the form of a diagnostic test has value because it allows the clinician to tailor his or her treatment decisions based on the test results. The expected value of clinical information (EVCI) is defined as the difference in expected outcome between testing and not testing. Hence, the testing option is only worth doing if the EVCI is positive.

What distinguishes diagnostic testing from screening is that in the former situation an individual presents with suspected disease based on his or her signs or symptoms. Testing options may involve the use of one test versus another, use of a sequence of tests, or the use of one positivity criterion versus another within one test. Evidence regarding diagnostic tests typically involves studies that estimate the sensitivity and specificity of the test, or possibly the receiver operator characteristic curve and area under the curve, but very few diagnostic test strategies have been evaluated in an integrated study, that is, a randomized clinical trial with patients randomized to different test strategies and followed until long-term outcomes are observed. Thus, decision models are very applicable to evaluating alternative diagnostic strategies because they can synthesize information on prior probability of disease, test characteristics, and treatment decisions conditional on test results.

### Treatment

We define treatment broadly, as any intervention that is available for an individual, who already has a clinical condition or disease, with an effect on the prognosis of that condition. Treatment decisions may include the choice of treatment versus no treatment, the choice among several available treatments, or the sequencing of treatment. Evidence on the effectiveness of treatments is usually fairly good, with adequate follow up. The added values of using a model when there is a good evidence base would be to extrapolate findings to other patient subgroups, extend intermediate endpoints to survival, or evaluate sequences of treatment without direct evidence.

## Roles of Systematic Reviews

Questions from stakeholders pertaining to any of the different types of clinical problems often prompt a systematic review of the evidence. There are fairly strict criteria for what may be called evidence and for determining the quality of evidence. Systematic reviews provide summary measures of the available evidence, as well as indicators of the quality of the evidence, but may fall short of providing outcomes that are synthesized in a way that would be most relevant for the decisionmaker(s). One of the challenges in conducting systematic reviews is how best to integrate different types of evidence. Evidence encountered by systematic reviewers can be either direct or indirect.14 Evidence is direct if it relates (in a single study) a health care intervention directly to the occurrence of a key health outcome that informs decisionmaking. For example, a randomized controlled trial that compares statin therapy with no therapy (placebo) with a primary endpoint of cardiovascular mortality provides direct evidence. Alternatively, a similar trial with an endpoint of low-density lipoprotein cholesterol levels would provide only indirect evidence. Indirect evidence requires two or more pieces of evidence to relate the health care intervention to the principal health outcome. The latter example requires evidence on the relationship between low-density lipoprotein cholesterol levels and cardiovascular mortality in addition to the relationship between statin therapy and low-density lipoprotein cholesterol levels.

Because much of the evidence pertaining to health care interventions is indirect, how the multiple bodies of evidence get synthesized, whether formally or informally, is critical to health care decisionmaking. Decision models provide a way to synthesize multiple pieces of direct evidence in cases where only indirect evidence exists on the relationship between an intervention and the health outcomes of interest. Decision models can be used to structure the linkages between the intervention and the key health outcomes, where direct evidence can be used to inform each link. Thus, even though both systematic reviews and decision models are used to combine data, we view systematic reviews as an interpolation of the evidence with a goal of enhancing our knowledge, and decision modeling as an extrapolation of the evidence with the goal of decisionmaking.

## Types of Models

In this section, we present the different types of decision-analytic model structures that are typically used in medical decisionmaking applications. We present a simplification of the taxonomy of model structures proposed by Brennan et al.15 We describe the key structural elements and the advantages and disadvantages of the following model types: decision trees, Markov (cohort) models, microsimulation (individual) models, dynamic models, and discrete event simulation models. The choice of what type of model to develop is typically related to the particular question at hand. The first three model types assume independence between individuals, while the latter two can model interactions among individuals, such as infectious disease transmission and restricted supplies of organs for transplantation. For a question with a relatively short time horizon, such as prevention of postoperative infections with no long-term sequelae, a simple decision tree may suffice. Questions pertaining to the prevention of infectious (communicable) diseases, such as the benefits of a childhood vaccination program, would require a dynamic model in order to capture the effects from herd immunity. Table 2 provides a summary of the different types of models, which are discussed in more detail below.

Table 2 Summary of types of decision model structures

Model Type | General Description | Type of Decision Best Suited For
Decision tree | Diagrams the risk of events and states of nature over a fixed time horizon. | Interventions for which the relevant time horizon is short and fixed.
Markov (cohort) model | Simulates a hypothetical cohort of individuals through a set of health states over time. | Modeling interventions for diseases or conditions that involve risk over a long time horizon and/or recurrent events.
Microsimulation (individual) model | Simulates one individual at a time; tracks the past health states of individual and models risk of future events stochastically. | Modeling complex disease processes, when Markov models are too limiting.
Dynamic model | System of differential equations that simulates the interactions between individuals and the spread of disease. | Modeling interventions for communicable diseases, such as vaccinations.
Discrete event simulation model | Simulates one individual at time as well as interactions among individuals or within a health care system. | Evaluating alternative health care systems (e.g., workflow, staffing) though flexible enough to address questions in several different areas.

### Decision Trees

A decision tree provides a logical structure of the decision and possible events as they unfold over time. The decision tree is made up of series of nodes and branches, and begins with a decision node (represented by a square) with all of the branches off of this node representing the different options available to the decisionmaker, such as treat, no treat, or test. Following these branches one can represent the events that can happen (e.g., patient has a positive test result) and the various states of nature that exist (e.g., patient has the disease of interest, though this is unknown to the decisionmaker) by a series of chance nodes (represented by circles) and branches (representing events or states). The probabilities of events or states of nature dictate the chance of going down one branch versus another, and can be estimated from data. Decision nodes can be placed “downstream” to represent a decision that is made later; for example, the decision to do an additional test if the first test is negative.

The terminal nodes that are placed at the end of each of the possible pathways in the decision tree represent the outcome(s) of interest after a specified time horizon. The outcome or set of outcomes that is specified should represent what is important to the decisionmaker. A decision tree can be computed either analytically (called a “rollback analysis”) to obtain the expected value of the health outcome associated with each strategy, or stochastically (i.e., where the outcomes are sampled) to obtain a measure of the variability in health outcomes in addition to the expected value. In some cases the outcome is very easy to quantify, such as whether the patient is dead or alive, that is, the optimal strategy will be the one that maximizes survival. For other cases the valued outcome is more qualitative in nature, such as levels of pain. Decision analysis, which includes the use of decision trees, uses utility theory or multiattribute utility theory to attach a value to all possible outcomes, which allows for a quantitative value to be assigned to a qualitative outcome in a manner that is consistent with the axioms of decisionmaking.4 The quantification of qualitative outcomes is, indeed, one of the criticisms of the decision-analytic approach. Suppose treatment A resulted in equal chances of no, mild, or severe pain, and treatment B resulted in equal chances of no or severe pain, with no chance of mild pain. A decision to go with treatment A implicitly values mild pain closer to no pain, whereas a decision to go with treatment B values mild pain closer to severe pain. Such implicit value judgments must be made all of the time in health care. Decision analysis provides the tools to make them explicit and transparent to the decisionmaker.

The primary advantage of using a decision tree over the other types of models is that decision trees are easy to follow and laid out in a very logical and linear fashion. Even in cases where the decision tree is quite “bushy,” the decisionmaker can view each of the possible pathways following an option, as well as the pathway probabilities. The primary disadvantage of a decision tree is that it is only applicable to situations where there are no (or very limited) recurring events and where the relevant time horizon is relatively short and fixed.

### Markov Models

Many clinical conditions involve recurring events at uncertain times over the lifetime of an individual. For interventions targeted towards these conditions, a decision tree is less suitable as it would become unwieldy if it had to represent all possible sequences of events over a lifetime (or alternative time horizon). For example, consider individuals with high cholesterol levels who are at increased risk for coronary heart disease. If we used a decision tree to evaluate the use of statin therapy for these patients we would have to specify a fixed time horizon. For example, we could model the likelihood of having coronary heart disease at 10 years and the likelihood of dying (from any cause) under the “treat” and “no treat” scenarios. However, this framework would not capture when the disease or death occurred within the 10-year time frame, which may be important. It would also not capture any events that may occur beyond 10 years. Hence, Markov models are ideal for modeling clinical problems that involve risk over time, or when the timing of events is important. Markov models consist of a defined set of mutually exclusive and collectively exhaustive health states, where a cohort of simulated individuals resides over time. Markov models also provide a useful tool for calculating life expectancy, as that is often an outcome in interest in medical decisionmaking. For example, simple Markov models can extend the time horizon of a decision tree with the sole purpose of calculating life expectancy with a two-state model (“alive” and “dead” states) using annual probabilities from a life table or adjusted life table. As with a decision tree, a Markov model can be computed either analytically to obtain the expected values of the outcomes or stochastically (i.e., where the outcomes are sampled) to obtain a measure of variability in health outcomes in addition to the expected value.

The advantage of using a Markov model is that this relatively standard modeling approach can capture many of the features present in a clinical process, such as risk of disease over time, changing health states over time and episodic events. The primary disadvantage is the underlying assumption that the probability of moving from one health state to another only depends on being in that state and does not depend on past history, either states visited in the past or time spent in that state. This assumption is known as the Markovian property and can be a very limiting assumption for clinical applications. The way that modelers get around this “memoryless” property is to create health state descriptions that include past history. For example, health states can be defined according to whether a stroke has occurred in the past, or perhaps even the number of or type of stroke. Health states can also be defined to include the number of years spent in a particular state. The impact of this is that the number of states can increase exponentially as the analyst attempts to include all of the relevant history for a clinical problem, which can result in a very large model that is difficult or sometimes impossible to manage.

### Microsimulation (Individual) Models

The distinguishing feature of a microsimulation model is that it simulates one individual at a time, also called first-order Monte Carlo simulations. There are other model types that involve individual sampling; we refer in this case to any model structure that assumes independence between individuals, that is, a decision tree-type structure or a Markov-type structure. A Markov model is most often analyzed as a single cohort progressing through the health states simultaneously, which does not allow one to distinguish one simulated individual from another except by the health state descriptions. A key feature of a microsimulation model, or more generically referred to as an individual sampling model, is that it allows the model to keep track of each simulated individual's history so that the number of health states can be greatly reduced. Microsimulation models can track multiple comorbidities, whether continuous or not, for each simulated individual and allow comorbidities to interact and affect patient outcomes. A microsimulation model can simulate events one cycle at a time, or can simulate time to an event by drawing from distributions, thereby modeling in continuous time.

The advantage of a microsimulation model is that it is flexible in how the disease process and intervention are modeled and overcomes many of the limitations inherent with Markov models. The disadvantages are that they can take a considerable amount of computer time to run, as they require sometimes millions of individuals to be simulated in order to get a stable estimate of the expected value. These types of models are also difficult to debug compared with traditional Markov models. Specifically, a Markov trace, which provides the proportions of the cohort in each state by cycle time, is a convenient tool for checking model accuracy and testing face validity.

### Dynamic Models

Dynamic models, or infectious disease models, are used when the disease of interest is communicable. These models typically use differential equations to simulate the interactions between humans (e.g., in the case of airborne or sexually transmitted infection), or humans and animals (e.g., in the case of zoonoses), and how these interactions affect that spread of a disease over time. These types of models can also include spatial details that are pertinent to the spread of communicable disease, such as the location of classes in a school affected by an influenza outbreak. The advantage of these models is that, since they include information on how interactions between individuals affect transmission, they can more accurately quantify the impact of different interventions on health outcomes, such as vaccination and its impact via herd immunity. Brisson and Edmunds demonstrate the differences between using a Markov (static) model and a dynamic model to model the effectiveness of the varicella vaccination.16 A limitation of these models is that, due to the complexity of programming, and the exponential increase in the number of differential equations needed to deal with the added complexity, they may, at times, include simplifications of complex programs such as screening programs. Examples include dynamic models of human papillomavirus and cervical cancer; to date these have failed to incorporate the detailed screening and triage strategies recommended by different policy groups, such as the American Society of Colposcopy and Cytopathology.17 They may also be less transparent than Markov models, since the programs used to develop these types of models include mathematics software such as MatLab or Mathematica.

### Discrete Event Simulation Models

Discrete event simulations are used primarily to evaluate systems. They have been applied to patient scheduling and admission rules, as well as patient routing and flow schemes.18 Unlike Markov models they do not model the likelihood of experiencing an event within a specified time step (i.e., Markov cycle) but model the distribution of time until the next event, using time as a continuous scale. An example of the type of applications for which discrete event simulation models are uniquely designed is the comparison of current laparoscopic surgical practice with a new model system in which patient care is handed off between two anesthesiologists in order to balance patient volume and safety.19 Another example is the evaluation of workflow models of parallel induction of anesthesia in the operating room to optimize facilities and use of resources.20 These types of applications are typically outside the scope of systematic reviews.

## Concerns With Modeling

Since the beginning of the use of decision-analytic models there has been a healthy amount of skepticism about their value. Many of the concerns raised by Henschke and Flehinger in their 1967 paper6 are still applicable today. In a 1979 “Sounding Board” article in The New England Journal of Medicine, Dr. William Schwartz discusses several major concerns of physicians, academicians, and students about decision analysis which echo those concerns raised by Henschke and Flehinger.21 One common criticism is that decision analysis requires quantification of all model parameters, and often the data aren't sufficient for such quantification, or that some outcomes are not quantifiable. This concern reveals the fundamental misconception about the goal of decision analysis: that it is an explicit and transparent approach to assist decisionmakers with complex decision when a decision must be made. Decisions are made every day with limited data, and implicit values are placed on qualitative outcomes; decision analysis provides the tool to help with this process. Another criticism is the concern that decisionmakers might not agree with the answer. For example, if a decision analysis showed that the risks of an intervention outweigh the benefits, this may be at odds with the conclusions that the decisionmaker would draw without the formal decision-analytic results. Again, since the goals of decision analysis are to assist the decisionmaker and not necessarily provide “the answer,” this situation should make explicit the decision process, with sensitivity analysis showing the effects of varying model parameters. These commonly voiced concerns about the use of decision models pose challenges for developing a framework to incorporate decision models into practice and will require that the methods and goals of decision analysis be made transparent to the decisionmaker.

## Models Alongside Systematic Reviews

Much of the discussion to this point has been focused on the structure and purpose of a decision model and the goals of decision analysis in general. However, the value of a model does rely to some extent on the quality and availability of the data available to inform the model parameters. One of the goals of systematic reviews is to promote evidence-based practice in everyday care in the form of systematic reviews conducted to assist key stakeholders with decisionmaking. While a thorough and systematic synthesis of the available evidence to date, along with information regarding the grade of evidence, is no doubt a powerful tool for decisionmakers, it may not always provide a sufficient amount of information to the decisionmaker. If the evidence is weak regarding one parameter/question (e.g., risks of mild side effects, specificity of a test), how much will that matter in the decisionmaking process of the stakeholder? If data are strong for one subgroup of the population, what can be said about other subgroups for which data are not particularly strong? If an intervention has a significant effect on a surrogate marker, how does that translate into endpoints that are most important to the decisionmaker? Decision analysis provides an explicit and transparent way to: (1) synthesize data from disparate sources, (2) extrapolate beyond the time horizons of available data, (3) extrapolate beyond surrogate markers, (4) quantify all of the relevant clinical outcomes, (5) evaluate parameter uncertainty, and (6) quantify the value of conducting further research.

Despite the obvious role that decision modeling can play in providing additional relevant data, the added value of a decision model alongside a systematic review has never been formally evaluated. For situations where the evidence base is sufficient for addressing the policy questions of interest, we would expect that the added value of a decision model would be minimal. For situations where data are insufficient for either some aspect of the question or for a population subgroup of interest, then we would expect that the potential value of adding a decision analysis to inform decisionmaking would be substantial because it would provide a rational and transparent framework. Without such a framework, the decisionmaker would need to fill in the data deficiencies using implicit values and judgments, or may opt for “not making a decision,” which in turn has relevant harms and benefits that may not be transparent to the decisionmaker. The addition of a decision model provides an objective, systematic, and explicit approach to decisionmaking that would enhance and clarify the decisionmaking process.

An important question arises regarding the quality of the evidence that goes into a decision model, which should ideally be connected with how model results are used to inform decisions. Typically, decision models include the best available evidence under the assumption that a decision will be made. However, there are certain “decisions” that may be more nuanced. For example, should a guidelines committee make a recommendation for the best strategy and provide the overall quality of the evidence informing that recommendation? Or, as is often the case, should guidelines fail to recommend anything in cases where the quality of the evidence is poor? Braithwaite and colleagues evaluated the cost-effectiveness of directly observed therapy for individuals with newly diagnosed HIV infection using a decision-analytic model.22 They conducted a series of analyses where they used different stringency of criteria for selecting which sources of evidence to use in the analyses. Often, the optimal decision found under both approaches is the same, as it is based on the strategy that maximizes an expected outcome, for example, quality-adjusted life years. However, the confidence with which one can state that one strategy is better is diminished if evidence of poorer quality is excluded. The choice of what levels of evidence to include in a decision analysis, or conducting a sensitivity analysis of varying the inclusion of different levels of evidence, should be the choice of the decisionmaker. Braithwaite and colleagues concluded that different a priori approaches may appeal to different types of decisionmakers: the “any data are better than no data” decisionmaker versus the “my judgment supersedes all but the best data” decisionmaker.22

An example of when modeling informed a systematic review is the 2007 U.S. Preventive Services Task Force (USPSTF) update of its recommendations for colorectal cancer screening.23 The Task Force requested a decision analysis for colorectal cancer to assist it in determining the age to begin and end screening, and intervals of screening for multiple screening tests, for which no direct evidence was available or likely ever to be available. This is the first time that the Task Force used a decision analysis in combination with a systematic evidence review to inform its decisions. Two modeling groups from the Cancer Intervention and Surveillance Modeling Network (CISNET) consortium provided standardized comparisons of 145 screening strategies using the best available evidence for consideration by USPSTF. The Task Force recommendations were published in fall 2008,^24^ along with the systematic review25 and decision analysis.26 The Task Force recommended a stop age for screening among those individuals who have screened consistently negative between ages 50 and 75; this is the first guideline for colorectal cancer screening to recommend a stop age.

## Issues Pertaining to a Modeling Framework

### What is a Model?

In order to explore the value of developing a model alongside systematic reviews, it is first important to define exactly what we mean by a model. Broadly speaking, a “model” can represent a physical structure that represents an actual entity (e.g., a model airplane) or can be a series of mathematical equations that describe supply and demand. See Weinstein et al. for a more detailed discussion of modeling for health care.27 For the purposes of decision modeling in health care, we define a decision model as a mathematical structure that describes the sequences of events and states of nature that can occur over time under alternative scenarios, that is, the alternative strategies available. A model provides a “virtual public health laboratory” to project out the average health outcomes associated with alternative policies, incorporating all of the evidence available to the decisionmaker. A decision model often incorporates mathematical functions that represent what we know about the disease, or the relationships between risk factors and disease, or disease and clinical outcomes. The impact of these assumptions can be evaluated in sensitivity analysis.

### Grading Models

To date there has been no development of a grading system to designate whether a decision-analytic model is “good” or “bad.” The idea of a model grading system is appealing because there is a high degree of skepticism and misunderstanding surrounding the usefulness of a model. However, it is commonly recognized that a grading system for decision models is unrealistic.28 Nonetheless, there are checklists that one can use (usually provided for cost-effectiveness analyses but some criteria apply more broadly to decision models) that cover basic analytic steps which every decision analysis should include, but should be viewed as minimal criteria. An example of such a checklist, adapted from the one suggested by Sculpher and colleagues28 is shown in Table 3. Even if one were to impose a criterion that models should include a natural history component, this may be difficult to judge in all cases.

Table 3 Minimal criteria for a high-quality decision model (adapted from Sculpher et al., 2000)28

Dimensions of Quality | Attributes of “Good Practice”
Structure | Model structure should be consistent with the stated decision problem. The structure should be dictated by theory of disease, and not by data availability.
Disease states | Model should reflect the time dependence of the disease process. States should reflect the underlying biological process of the disease and the impact of intervention, rather than health services inputs. The number of states should be manageable, reflect all important aspects of disease, and not be omitted on the basis of lack of data.
Options | Options and strategies should not be limited by constraints of currently accepted clinical practice. A balance is needed between full range of options and keeping decision problem manageable.
Time horizon | The time horizon should be sufficient to capture all important health outcomes. Lifetime time horizons will be appropriate for many models; shorter time horizons can be justified according to understanding the disease process (e.g., impact on morbidity and not mortality) and effect of interventions.
Cycle length (if relevant) | The length of a cycle should be the minimum interval over which pathology and/or symptoms in patients is expected to alter. The analyst should justify the selection of the cycle length in terms of disease process.
Data identification | It is inappropriate to criticize a model because of lack of data. “Best available” data should be referred to as “optimal available” data as it is an empirical question whether acquiring all existing evidence is a good use of resources. Models can be used to undertake formal value of information analysis to determine the optimal data to incorporate. Analyst should make clear all low-cost sources have been searched for the appropriate parameter values. Methods used for parameter identification when no data are identified should be fully detailed.
Data incorporation | The process of data incorporation should follow accepted methods of epidemiology and statistics. Different sources of uncertainty should be distinguished (uncertainty, heterogeneity, first- and second-order uncertainty). Interval rates should be translated into transition probabilities using appropriate formula. Models should use half-cycle correction.
Internal consistency | The model should be checked and tested by the analyst (debugging).
External consistency | If possible, the model outputs should be compared to the results from relevant primary research studies (not used to inform model inputs).

### Modeling Results

The process of building a decision model can be instructive to the decisionmaker, as it requires one to be explicit about the uncertain events and the true states of nature. It also requires careful thinking about what the possible comparison strategies are and for whom. Once a model is developed and the relevant parameters are quantified (ideally informed by a systematic review, when applicable) there are several analyses that can be conducted with the decision model, as outlined below.

#### Base-Case Analysis

This analysis estimates the expected values of the clinical outcomes associated with each strategy. The outcome could be a composite outcome that combines length of life and quality of life (e.g., quality-adjusted life years) or it could be a disease-specific outcome (e.g., number of acute events over a person's lifetime). The base-case analysis provides a ranking of all of the strategies using the best estimates for all of the input parameters.

#### Sensitivity Analysis

In one-way sensitivity analysis, the analyst varies each of the parameters one at a time within a clinically plausible range (or 95 percent confidence interval) to determine which parameters have the most impact on the base-case results. Two-way (or three-way) sensitivity analysis can be performed by varying two (or three) parameters simultaneously, though this type of sensitivity analysis gets impractical above three parameters.

#### Probabilistic Sensitivity Analysis

To evaluate all of the parameter uncertainty simultaneously, point estimates in the model can be replaced with probability distributions, where the mean of the distribution reflects the best estimate of the parameter and the variance reflects the uncertainty of the mean. For example, a commonly used distribution for probability estimates is the beta distribution since it is bound between 0 and 1. The model is then run many times (e.g., 1,000 simulations). For each simulation model, parameter values are randomly drawn from each of the distributions and the expected model outcome is recorded. The 1,000 simulations result in a distribution of expected model outcomes (e.g., quality-adjusted life expectancies for each strategy), which reflects the overall parameter uncertainty in the model.

#### Value of Information Analysis

While probabilistic sensitivity analysis describes the uncertainty in the model outputs based on the uncertainty in the model inputs, value of information analysis describes (in health terms) the “value” associated with reducing the uncertainty (in the form of conducting further studies) of one or more parameters. The notion is that by gathering more information on a parameter, we would reduce the variance of the distribution for that parameter and thus increase our chances of making a better decision. Hence, the increase in the probability in making a better decision leads to better clinical outcomes. Value of information analysis is most often done within a cost-effectiveness framework, where the value of further research is valued in terms of costs (using a specified willingness to pay threshold for a quality-adjusted year of life gained).

## Summary Statement

While the underpinnings of decision analysis have a long history, the applications to health care have only occurred within the last 5 decades. The methods of decision analysis provide a systematic and explicit way to examine a decision process and are an obvious companion for systematic reviews when there are limitations in the evidence base, or multiple sources of evidence that require synthesis. There are several types of decision models available that are appropriate for different types of clinical questions. However, they are all used for the same purpose: to assist in decisionmaking under uncertainty when a decision must be made.