# Excluded Studies

1 Summaries for patients. The cost effectiveness of screening the U.S. blood supply for West Nile virus. Annals of Internal Medicine. Oct. 4. 2005;143(7):44. Cost only.
2 Summaries for patients. The cost effectiveness of strategies to prevent type 2 diabetes. Annals of Internal Medicine. Mar. 1. 2005;142(5):28. Cost only. [pmid: 15630107].
3 Summaries for patients. Cost effectiveness of a vaccine to prevent herpes zoster (shingles) in older adults. Annals of Internal Medicine. Sep. 5. 2006;145(5):14. Cost only.
4 Summaries for patients. The cost effectiveness of preventive strategies for breast and ovarian cancer for women with BRCA1 or BRCA2 mutations. Annals of Internal Medicine. Mar. 21. 2006;144(6):40. Cost only.
5 Summaries for patients. The cost effectiveness of aspirin, statins, or both drugs in the primary prevention of heart disease. Annals of Internal Medicine. Mar. 7. 2006;144(5):29. Cost only. [pmid: 16389252].
6 Abbas I, Rovira J, Casanovas J. Clinical trial optimization: Monte Carlo simulation Markov model for planning clinical trials recruitment. Contemporary Clinical Trials. May. 2007;28(3):220. Off topic. [pmid: 16979387].
7 Abbas I, Rovira J, Casanovas J, et al. Optimal design of clinical trials with computer simulation based on results of earlier trials, illustrated with a lipodystrophy trial in HIV patients. Journal of Biomedical Informatics. Dec. 2008;41(6):1053. Off topic. [pmid: 18534916].
8 Abrahamsen B. Comment on Schott et al.: which screening strategy using BMD measurements would be most cost effective for hip fracture prevention in elderly women? A decision analysis based on a Markov model. Osteoporosis International. author reply 701. May. 18. 2007;(5):699. Cost only. [pmid: 17334679].
9 Adam MA, Johnson LF. Estimation of adult antiretroviral treatment coverage in South Africa. South African Medical Journal Suid-Afrikaanse Tydskrif Vir Geneeskunde. Sep. 2009;99(9):661-7. Off topic. [pmid: 20073293].
10 Ades AE, Claxton K, Sculpher M. Evidence synthesis, parameter correlation and probabilistic sensitivity analysis. Health economics. Apr. 2006;15(4):373. Off topic. [pmid: 16389628].
11 Ahmed M, Munshi SU, Nessa A, et al. High prevalence of hepatitis A virus antibody among Bangladeshi children and young adults warrants pre-immunization screening of antibody in HAV vaccination strategy. Indian Journal of Medical Microbiology. Jan-Mar. 2009;27(1):48-50. Costs only. [pmid: 19172060].
12 Akazawa M, Stearns SC, Biddle AK. Assessing treatment effects of inhaled corticosteroids on medical expenses and exacerbations among COPD patients: longitudinal analysis of managed care claims. Health services research. Dec. 2008;43(6):2164. Statistical analysis. [pmid: 18671750].
13 Alagoz O, Bryce CL, Shechter S, et al. Incorporating biological natural history in simulation models: empirical estimates of the progression of end stage liver disease. Medical Decision Making. Nov-Dec. 2005;25(6):620. Off topic. [pmid: 16282213].
14 Al-Badriyeh D, Liew D, Stewart K, et al. Cost-effectiveness evaluation of voriconazole versus liposomal amphotericin B as empirical therapy for febrile neutropenia in Australia. Journal of Antimicrobial Chemotherapy. Jan. 2009;63(1):197. Cost only. [pmid: 19001450].
15 Albers-Heitner P, Berghmans B, Joore M, et al. The effects of involving a nurse practitioner in primary care for adult patients with urinary incontinence: the PromoCon study (Promoting Continence). BMC Health Services Research. 2008;8:84. Off topic. [pmid: 18412964].
16 Albrechtsen A, Sand Korneliussen T, Moltke I, et al. Relatedness mapping and tracts of relatedness for genome-wide data in the presence of linkage disequilibrium. Genetic Epidemiology. Apr. 2009;33(3):266-74. Off topic. [pmid: 19025785].
17 Aleem IS, Karamlou T, Benson LN, et al. Transcatheter device versus surgical closure of ventricular septal defects: a clinical decision analysis. Catheterization & Cardiovascular Interventions. Apr. 2006;67(4):630. Statistical Analysis. [pmid: 16548005].
18 Alexander BD, Ashley ED, Reller LB, et al. Cost savings with implementation of PNA FISH testing for identification of Candida albicans in blood cultures. Diagnostic Microbiology & Infectious Disease. Apr. 2006;54(4):277. Cost only. [pmid: 16466898].
19 Allenspach K, Bell J, Whittlestone KD. Interactive clinical cases in veterinary education used to promote independent study. Journal of Veterinary Medical Education. 2008;35(4):589. Off topic. [pmid: 19228913].
20 Alolabi B, Bajammal S, Shirali J, et al. Treatment of displaced femoral neck fractures in the elderly: a cost-benefit analysis. Journal of Orthopaedic Trauma. Jul. 2009;23(6):442-6. Costs only. [pmid: 19550232].
21 Altes HK, Dijkstra F, Lugner A, et al. Targeted BCG vaccination against severe tuberculosis in low-prevalence settings: epidemiologic and economic assessment. Epidemiology. Jul. 2009;20(4):562. Cost only. [pmid: 19295437].
22 Anderson AM, Mirka GA, Joines SMB, et al. Analysis of alternative keyboards using learning curves. Human Factors. Feb. 2009;51(1):35-45. Off topic. [pmid: 19634307].
23 Anderson KP. Cost effectiveness of ICDs. New England Journal of Medicine. author reply 205-7. Jan. 12. 2006;354(2):205. Cost only. [pmid: 16407520].
24 Angelucci E, Barosi G, Camaschella C, et al. Italian Society of Hematology practice guidelines for the management of iron overload in thalassemia major and related disorders. Haematologica. May. 2008;93(5):741. Off topic. [pmid: 18413891].
25 Annemans L, Van Cutsem E, Humblet Y, et al. Cost effectiveness of cetuximab in combination with irinotecan compared with current care in metastatic colorectal cancer after failure on irinotecan a Belgian analysis. Acta Clinica Belgica. Nov Dec. 2007;62(6):419. Statistical Analysis. [pmid: 18351186].
26 Anonychuk AM, Tricco AC, Bauch CT, et al. Cost effectiveness analyses of hepatitis A vaccine: a systematic review to explore the effect of methodological quality on the economic attractiveness of vaccination strategies. PharmacoEconomics. 2008;26(1):17. Review. [pmid: 18088156].
27 Aoki N, Sakai M, Nakayama T, et al. u SHARE: web based decision support/risk communication tool for healthcare consumers with unruptured intracranial aneurysms. Studies in Health Technology & Informatics. 2007;129(Pt 2):1012. Off topic. [pmid: 17911868].
28 Appleby J, Devlin N, Parkin D. NICE's cost effectiveness threshold. Bmj. Aug. 25. 2007;335(7616):358. Cost only. [pmid: 17717337].
29 Ara R, Rafia R, Ward SE, et al. Are intensive lipid-lowering regimens an optimal economic strategy in patients with ACS? An acute and chronic perspective. Expert Review of Pharmacoeconomics & Outcomes Research. Oct. 2009;9(5):423-33. Review. [pmid: 19817526].
30 Archer J, Southall N. Does cost-benefit analysis or self-control predict involvement in bullying behavior by male prisoners?. Aggressive Behavior. Jan-Feb. 2009;35(1):31-40. Off topic. [pmid: 18942112].
31 Archer J, Young W. Signal treatments to reduce heavy vehicle crash-risk at metropolitan highway intersections. Accident Analysis & Prevention. May. 2009;41(3):404-11. Off topic. [pmid: 19393785].
32 Armstrong MB, Schumacher KR, Mody R, et al. Bortezomib as a therapeutic candidate for neuroblastoma. Journal of experimental therapeutics & oncology. 2008;7(2):135. Off topic. [pmid: 18771087].
33 Arnesen T, Trommald M. Are QALYs based on time trade off comparable? A systematic review of TTO methodologies. Health economics. Jan. 2005;14(1):39. Off topic. [pmid: 15386674].
34 Arwood E, Kaakinen J. SIMulation based on language and learning (SIMBaLL): the model. International Journal of Nursing Education Scholarship. 2009;6(1). Article9. Off topic.
35 Aspirot A, Puligandla PS, Bouchard S, et al. A contemporary evaluation of surgical outcome in neonates and infants undergoing lung resection. Journal of pediatric surgery. Mar. 2008;43(3):508. Statistical analysis. [pmid: 18358290].
36 Atik OS, Gunal I, Korkusuz F. Burden of osteoporosis. Clinical Orthopaedics & Related Research. Feb. 2006;443:19. Off topic. [pmid: 16462421].
37 Atthobari J, Asselbergs FW, Boersma C, et al. Cost effectiveness of screening for albuminuria with subsequent fosinopril treatment to prevent cardiovascular events: A pharmacoeconomic analysis linked to the prevention of renal and vascular endstage disease (PREVEND) study and the prevention of renal and vascular endstage disease intervention trial (PREVEND IT). Clinical therapeutics. Mar. 2006;28(3):432. Statistical Analysis. [pmid: 16750458].
38 Augusto V, Xie X. Redesigning pharmacy delivery processes of a health care complex. Health Care Management Science. Jun. 2009;12(2):166-78. Off topic. [pmid: 19469456].
39 Augustovski FA, Garcia Marti S, Pichon-Riviere A, et al. Childhood pneumococcal disease burden in Argentina. Pan American Journal of Public Health. May. 2009;25(5):423-30. Off topic. [pmid: 19695132].
40 Ba SO, Odobez JM. Recognizing visual focus of attention from head pose in natural meetings. IEEE Transactions on Systems, Man, & Cybernetics, Part B: Cybernetics. Feb. 2009;39(1):16-33. Off topic.
41 Bae SJ, Paltiel AD, Fuhlbrigge AL, et al. Modeling the potential impact of a prescription drug copayment increase on the adult asthmatic medicaid population. Value in Health. Jan Feb. 2008;11(1):110. Off topic. [pmid: 18237365].
42 Bagshaw SM. The long term outcome after acute renal failure. Current opinion in critical care. Dec. 2006;12(6):561. Off topic. [pmid: 17077687].
43 Bakhai A, Stone GW, Mahoney E, et al. Cost effectiveness of paclitaxel eluting stents for patients undergoing percutaneous coronary revascularization: results from the TAXUS IV Trial. Journal of the American College of Cardiology. Jul. 18. 2006;48(2):253. Statistical Analysis. [pmid: 16843171].
44 Bala MV, Mauskopf JA. Optimal assignment of treatments to health states using a Markov decision model: an introduction to basic concepts. PharmacoEconomics. 2006;24(4):345. Off topic. [pmid: 16605281].
45 Bala MV, Zarkin GA, Mauskopf J. Presenting results of probabilistic sensitivity analysis: the incremental benefit curve. Health economics. Mar. 2008;17(3):435. Off topic. [pmid: 17694580].
46 Banerjee A. Temporal changes in the spatial pattern of disease rates incorporating known risk factors. Social science & medicine. Jul. 2007;65(1):7. Off topic. [pmid: 17509742].
47 Bansback NJ, Regier DA, Ara R, et al. An overview of economic evaluations for drugs used in rheumatoid arthritis : focus on tumour necrosis factor alpha antagonists. Drugs. 2005;65(4):473. Review. [pmid: 15733011].
48 Barbieri M, Drummond M, Willke R, et al. Variability of cost effectiveness estimates for pharmaceuticals in Western Europe: lessons for inferring generalizability. Value in Health. Jan-Feb. 2005;8(1):10. Review. [pmid: 15841890].
49 Barham L, Lewis D, Latimer N. One to one interventions to reduce sexually transmitted infections and under the age of 18 conceptions: a systematic review of the economic evaluations. Sexually transmitted infections. Oct. 2007;83(6):441. Review. [pmid: 17626115].
50 Barnighausen T, Bloom DE. “Conditional scholarships” for HIV/AIDS health workers: educating and retaining the workforce to provide antiretroviral treatment in sub-Saharan Africa. Social Science & Medicine. Feb. 2009;68(3):544-51. Off topic. [pmid: 19081662].
51 Baron J. A decision analysis of consent. American Journal of Bioethics. May-Jun. 2006;6(3):46. Cost only. [pmid: 16754453].
52 Barrett JS, Mondick JT, Narayan M, et al. Integration of modeling and simulation into hospital based decision support systems guiding pediatric pharmacotherapy. BMC Medical Informatics & Decision Making. 2008;8:6. Decision aid. [pmid: 18226244].
53 Barton GR, Stacey PC, Fortnum HM, et al. Hearing impaired children in the United Kingdom, IV: cost effectiveness of pediatric cochlear implantation. Ear & Hearing. Oct. 2006;27(5):575. Statistical Analysis. [pmid: 16957506].
54 Bastarrika G, Thilo C, Headden GF, et al. Cardiac CT in the assessment of acute chest pain in the emergency department. AJR.American Journal of Roentgenology. Aug. 2009;193(2):397. Review. [pmid: 19620436].
55 Basu A, Meltzer D. Implications of spillover effects within the family for medical cost effectiveness analysis. Journal of health economics. Jul. 2005;24(4):751. Off topic. [pmid: 15960995].
56 Basu A, Meltzer D. Value of information on preference heterogeneity and individualized care. Medical Decision Making. Mar Apr. 2007;27(2):112. Off topic. [pmid: 17409362].
57 Basu A, Meltzer HY, Dukic V. Estimating transitions between symptom severity states over time in schizophrenia: a Bayesian meta analytic approach. Statistics in medicine. Sep. 15. 2006;25(17):2886. Statistical Analysis. [pmid: 16220519].
58 Baykasoglu A, Dereli T, Yilankirkan N. Application of cost/benefit analysis for surgical gown and drape selection: a case study. American Journal of Infection Control. Apr. 2009;37(3):215-26. Off topic. [pmid: 19216004].
59 Beauchamp CL, Beauchamp GR, Stager DR Sr., et al. The cost utility of strabismus surgery in adults. Journal of Aapos: American Association for Pediatric Ophthalmology & Strabismus. Oct. 2006;10(5):394. Statistical Analysis.
60 Beigi RH, Bunge K, Song Y, et al. Epidemiologic and economic effect of methicillin-resistant Staphylococcus aureus in obstetrics. Obstetrics & Gynecology. May. 2009;113(5):983. Cost Only. [pmid: 19384112].
61 Bell CM, Urbach DR, Ray JG, et al. Bias in published cost effectiveness studies: systematic review. Bmj. Mar. 25. 2006;332(7543):699. Review. [pmid: 16495332].
62 Belmin J, Pariel-Madjlessi S, Surun P, et al. The cognitive disorders examination (Codex) is a reliable 3 minute test for detection of dementia in the elderly (validation study on 323 subjects). Presse Medicale. Sep. 2007;36(9 Pt 1):1183. Off topic.
63 Benbassat J, Baumal R. The time horizons of formal decision analyses. Qjm. Jun. 2007;100(6):383. Off topic. [pmid: 17483495].
64 Beresniak A, Russell AS, Haraoui B, et al. Advantages and limitations of utility assessment methods in rheumatoid arthritis. Journal of Rheumatology. Nov. 2007;34(11):2193. Off topic. [pmid: 17937471].
65 Bergman JJ. Diagnosis and therapy of early neoplasia in Barrett's esophagus. Current opinion in gastroenterology. Jul. 2005;21(4):466. Review. [pmid: 15930990].
66 Bergman JJ. Gastroesophageal reflux disease and Barrett's esophagus. Endoscopy. Jan. 2005;37(1):8. Off topic. [pmid: 15657852].
67 Bergstrand M, Soderlind E, Weitschies W, et al. Mechanistic modeling of a magnetic marker monitoring study linking gastrointestinal tablet transit, in vivo drug release, and pharmacokinetics. Clinical Pharmacology & Therapeutics. Jul. 2009;86(1):77-83. Off topic. [pmid: 19387437].
68 Bertin KC. Minimally invasive outpatient total hip arthroplasty: a financial analysis. Clinical Orthopaedics & Related Research. Jun. 2005;(435):154. Cost Only. [pmid: 15930933].
69 Beutels P, Thiry N, Van Damme P. Convincing or confusing? Economic evaluations of childhood pneumococcal conjugate vaccination a review (2002 2006). Vaccine. Feb. 9. 2007;25(8):1355. Review. [pmid: 17208339].
70 Bhuridej P, Kuthy RA, Flach SD, et al. Four year cost utility analyses of sealed and nonsealed first permanent molars in Iowa Medicaid enrolled children. Journal of public health dentistry. 2007;67(4):191. Statistical Analysis. [pmid: 18087989].
71 Bichey BG, Miyamoto RT. Outcomes in bilateral cochlear implantation. Otolaryngology Head & Neck Surgery. May. 2008;138(5):655. Off topic. [pmid: 18439474].
72 Binquet C, Le Teuff G, Abramamovicz M, et al. Markov modelling of HIV infection evolution in the HAART era. Epidemiology & Infection. Sep. 2009;137(9):1272. Decision aid. [pmid: 19134234].
73 Birch S, Gafni A. The biggest bang for the buck or bigger bucks for the bang: the fallacy of the cost effectiveness threshold. Journal of Health Services & Research Policy. Jan. 2006;11(1):46. Off topic.
74 Black C, Bagust A, Boland A, et al. The clinical effectiveness and cost effectiveness of computed tomography screening for lung cancer: systematic reviews. Health technology assessment (Winchester, England). 1. 90. Jan. 2006;10(3):ix-x. iii. Review.
75 Bleichrodt H, Doctor J, Stolk E. A nonparametric elicitation of the equity efficiency trade off in cost utility analysis. Journal of health economics. Jul. 2005;24(4):655. Off topic. [pmid: 15960990].
76 Blough DK, Ramsey S, Sullivan SD, et al. The impact of using different imputation methods for missing quality of life scores on the estimation of the cost-effectiveness of lung-volume-reduction surgery. Health economics. Jan. 2009;18(1):91. Off topic. [pmid: 18435426].
77 Bochud PY, Cai T, Overbeck K, et al. Genotype 3 is associated with accelerated fibrosis progression in chronic hepatitis C. Journal of Hepatology. Oct. 2009;51(4):655-66. Off topic. [pmid: 19665246].
78 Bodger K. Economic implications of biological therapies for Crohn's disease: review of infliximab. PharmacoEconomics. 2005;23(9):875. Review. [pmid: 16153132].
79 Bojke L, Sculpher M, Stephens R, et al. Cost effectiveness of increasing the dose intensity of chemotherapy with granulocyte colony stimulating factor in small cell lung cancer: based on data from the Medical Research Council LU19 trial. PharmacoEconomics. 2006;24(5):443. Statistical Analysis. [pmid: 16706570].
80 Bolwell BJ. Factors predicting success or failure associated with common types of transplants. Pediatric transplantation. Dec. 2005;9(Suppl 7):2. Off topic. [pmid: 16305613].
81 Bonay M, Bancal C, Crestani B. The risk/benefit of inhaled corticosteroids in chronic obstructive pulmonary disease. Expert Opinion on Drug Safety. Mar. 2005;4(2):251. Off topic. [pmid: 15794718].
82 Boos N. The impact of economic evaluation on quality management in spine surgery. European Spine Journal. Aug. Suppl 3. 2009;18:338-47. Off topic. [pmid: 19337760].
83 Bosanquet N, Yeates A. Modelling the cost effectiveness of cholinesterase inhibitors in the management of mild to moderately severe Alzheimer's disease. PharmacoEconomics. author reply 625-6. 2006;24(6):623. Cost only. [pmid: 16761908].
84 Bosmans JE, de Bruijne MC, van Hout HP, et al. Practical guidelines for economic evaluations alongside equivalence trials. Value in Health. Mar Apr. 2008;11(2):251. Off topic. [pmid: 18380637].
85 Bottomley JM, Raymond FD. Pharmaco economic issues for diabetes therapy. Best Practice & Research Clinical Endocrinology & Metabolism. Dec. 2007;21(4):657. Review. [pmid: 18054741].
86 Bouchard P, Renouard F, Bourgeois D, et al. Cost-effectiveness modeling of dental implant vs. bridge. Clinical oral implants research. Jun. 2009;20(6):583. Cost Only. [pmid: 19530315].
87 Boyd KA, Briggs AH. Cost-effectiveness of pharmacy and group behavioural support smoking cessation services in Glasgow. Addiction. Feb. 2009;104(2):317. Off topic. [pmid: 19149829].
88 Bozic KJ, Kurtz SM, Lau E, et al. The epidemiology of revision total knee arthroplasty in the United States. Clinical Orthopaedics & Related Research. Jan. 2010;468(1):45-51. Off topic. [pmid: 19554385].
89 Bozzette SA. Routine screening for HIV infection timely and cost effective. New England Journal of Medicine. Feb. 10. 2005;352(6):620. Cost only. [pmid: 15703428].
90 Bradley RK, Roberts A, Smoot M, et al. Fast statistical alignment. PLoS Computational Biology. May. 2009;5(5):e1000392. Off topic. [pmid: 19478997].
91 Bradshaw D, Norman R, Pieterse D, et al. Estimating the burden of disease attributable to diabetes in South Africa in 2000. South African Medical Journal.Suid Afrikaanse Tydskrif Vir Geneeskunde. Aug. 2007;97(8 Pt 2):700. Off topic. [pmid: 17952227].
92 Brainerd CJ, Reyna VF, Howe ML. Trichotomous processes in early memory development, aging, and neurocognitive impairment: a unified theory. Psychological Review. Oct. 2009;116(4):783-832. Off topic. [pmid: 19839684].
93 Braithwaite RS, Meltzer DO, King JT Jr., et al. What does the value of modern medicine say about the $50,000 per quality adjusted life year decision rule?. Medical care. Apr. 2008;46(4):349. Off topic. [pmid: 18362813].
94 Braithwaite RS, Roberts MS, Justice AC. Incorporating quality of evidence into decision analytic modeling. Annals of Internal Medicine. Jan. 16. 2007;146(2):133. Off topic. [pmid: 17227937].
95 Braithwaite RS, Shechter S, Chang CC, et al. Estimating the rate of accumulating drug resistance mutations in the HIV genome. Value in Health. May Jun. 2007;10(3):204. Off topic. [pmid: 17532813].
96 Brauer CA, Bozic KJ. Using observational data for decision analysis and economic analysis. Journal of Bone & Joint Surgery American Volume. May. 2009;91(Suppl 3):73. Off topic.
97 Brauer CA, Rosen AB, Greenberg D, et al. Trends in the measurement of health utilities in published cost utility analyses. Value in Health. Jul-Aug. 2006;9(4):213. Off topic. [pmid: 16903990].
98 Brauer CA, Rosen AB, Olchanski NV, et al. Cost utility analyses in orthopaedic surgery. Journal of Bone & Joint Surgery American Volume. Jun. 2005;87(6):1253. Review.
99 Brauer CA, Waters PM. An economic analysis of the timing of microsurgical reconstruction in brachial plexus birth palsy. Journal of Bone & Joint Surgery American Volume. May. 2007;89(5):970. Cost Only.
100 Bravo Vergel Y, Sculpher M. Quality adjusted life years. Practical Neurology. Jun. 2008;8(3):175. Off topic. [pmid: 18502950].
101 Brazier J, Akehurst R, Brennan A, et al. Should patients have a greater role in valuing health states?. Applied Health Economics & Health Policy. 2005;4(4):201. Off topic. [pmid: 16466271].
102 Brazier J, Tumur I, Holmes M, et al. Psychological therapies including dialectical behaviour therapy for borderline personality disorder: a systematic review and preliminary economic evaluation. Health technology assessment (Winchester, England). 1. 117. Sep. 2006;10(35):ix-xii. iii. ix. Review.
103 Bress JN, Hulgan T, Lyon JA, et al. Agreement of decision analyses and subsequent clinical studies in infectious diseases. American Journal of Medicine. May. 2007;120(5):461.e1. Off topic. [pmid: 17466659].
104 Briggs A. Probabilistic analysis of cost effectiveness models: statistical representation of parameter uncertainty. Value in Health. Jan-Feb. 2005;8(1):1. Cost only. [pmid: 15841888].
105 Briggs AH, Lozano-Ortega G, Spencer S, et al. Estimating the cost effectiveness of fluticasone propionate for treating chronic obstructive pulmonary disease in the presence of missing data. Value in Health. Jul-Aug. 2006;9(4):227. Statistical Analysis. [pmid: 16903992].
106 Brisson M, Edmunds WJ. Impact of model, methodological, and parameter uncertainty in the economic analysis of vaccination programs. Medical Decision Making. Sep-Oct. 2006;26(5):434. Off topic. [pmid: 16997923].
107 Brixner DI, McAdam-Marx C. Cost effectiveness of insulin analogs. American Journal of Managed Care. Nov. 2008;14(11):766. Review. [pmid: 18999911].
108 Brooker S, Kabatereine NB, Fleming F, et al. Cost and cost effectiveness of nationwide school based helminth control in Uganda: intra country variation and effects of scaling up. Health Policy & Planning. Jan. 2008;23(1):24. Off topic. [pmid: 18024966].
109 Brooks JM, Fang G. Interpreting treatment-effect estimates with heterogeneity and choice: simulation model results. Clinical Therapeutics. Apr. 2009;31(4):902-19. Statistical analysis. [pmid: 19446162].
110 Brothers TE, Robison JG, Elliott BM. Prospective decision analysis for peripheral vascular disease predicts future quality of life. Journal of Vascular Surgery. discussion 708. Oct. 2007;46(4):701. Statistical Analysis. [pmid: 17765449].
111 Brouwer WB, Niessen LW, Postma MJ, et al. Need for differential discounting of costs and health effects in cost effectiveness analyses. BMJ. Aug. 20. 2005;331(7514):446. Cost Only. [pmid: 16110075].
112 Brouwer WB, van Exel NJ, Baltussen RM, et al. A dollar is a dollar is a dollar or is it?. Value in Health. Sep-Oct. 2006;9(5):341. Off topic. [pmid: 16961552].
113 Brown GC, Brown MM. Cost effectiveness. Ophthalmology. author reply 1433 4. Aug. 2008;115(8):1433. No abstract. [pmid: 18675701].
114 Brown GC, Brown MM, Brown HC, et al. The goal of value based medicine analyses: comparability. The case for neovascular macular degeneration. Transactions of the American Ophthalmological Society. discussion 169 71. 2007;105:160. Review. [pmid: 18427606].
115 Brown GC, Brown MM, Brown HC, et al. A value based medicine comparison of interventions for subfoveal neovascular macular degeneration. Ophthalmology. Jun. 2007;114(6):1170. Statistical Analysis. [pmid: 17320964].
116 Brown MM, Brown GC, Brown HC, et al. The comparative effectiveness and cost effectiveness of vitreoretinal interventions. Current opinion in ophthalmology. May. 2008;19(3):202. Review. [pmid: 18408494].
117 Brown MM, Luo B, Brown HC, et al. Comparative effectiveness: its role in the healthcare system. Current opinion in ophthalmology. May. 2009;20(3):188. Off topic. [pmid: 19425205].
118 Bryan S, Williams I, McIver S. Seeing the NICE side of cost effectiveness analysis: a qualitative investigation of the use of CEA in NICE technology appraisals. Health economics. Feb. 2007;16(2):179. Off topic. [pmid: 16960851].
119 Bryant J, Brodin H, Loveman E, et al. The clinical and cost effectiveness of implantable cardioverter defibrillators: a systematic review. Health technology assessment (Winchester, England). Sep. 2005;9(36):iii. 1. Review.
120 Bryant J, Clegg AJ, Sidhu MK, et al. Systematic review of the Sugarbaker procedure for pseudomyxoma peritonei. British Journal of Surgery. Feb. 2005;92(2):153. Review. [pmid: 15685704].
121 Buchanan DR, O'Mara AM, Kelaghan JW, et al. Challenges and recommendations for advancing the state of the science of quality of life assessment in symptom management trials. Cancer. Oct. 1. 2007;110(7):1621. Off topic. [pmid: 17868120].
122 Buckingham KJ, Devlin NJ. A note on the nature of utility in time and health and implications for cost utility analysis. Social science & medicine. Jan. 2009;68(2):362. Off topic. [pmid: 19019518].
123 Budke CM, Jiamin Q, Qian W, et al. Economic effects of echinococcosis in a disease endemic region of the Tibetan Plateau. American Journal of Tropical Medicine & Hygiene. Jul. 2005;73(1):2. Statistical Analysis. [pmid: 16014823].
124 Buskens E, Meijboom MJ, Kooijman H, et al. The use of a surgical sealant (CoSeal) in cardiac and vascular reconstructive surgery: an economic analysis. Journal of Cardiovascular Surgery. Apr. 2006;47(2):161. Cost Only. [pmid: 16572090].
125 Byrne MM, O'Malley K, Suarez-Almazor ME. Willingness to pay per quality adjusted life year in a study of knee osteoarthritis. Medical Decision Making. Nov-Dec. 2005;25(6):655. Off topic. [pmid: 16282216].
126 Campbell H, Briggs A, Buxton M, et al. The credibility of health economic models for health policy decision making: the case of population screening for abdominal aortic aneurysm. Journal of Health Services & Research Policy. Jan. 2007;12(1):11. Review.
127 Campbell JD, Spackman DE, Sullivan SD. Health economics of asthma: assessing the value of asthma interventions. Allergy. Dec. 2008;63(12):1581. Review. [pmid: 19032230].
128 Canoui-Poitrine F, Jeanblanc G, Alberti C, et al. Cost effectiveness of sirolimus-eluting stents compared with bare metal stents in acute myocardial infarction: insights from the TYPHOON trial. Applied Health Economics & Health Policy. 2009;7(1):19. Off topic. [pmid: 19558192].
129 Canter PH, Coon JT, Ernst E. Cost effectiveness of complementary treatments in the United Kingdom: systematic review. BMJ. Oct. 15. 2005;331(7521):880. Cost only. [pmid: 16223821].
130 Carlson JJ, Henrikson NB, Veenstra DL, et al. Economic analyses of human genetics services: a systematic review. Genetics in Medicine. Oct. 2005;7(8):519. Review. [pmid: 16247290].
131 Carr VJ, Lewin TJ, Neil AL. What is the value of treating schizophrenia?. Australian & New Zealand Journal of Psychiatry. Nov-Dec. 2006;40(11 12):963. Off topic. [pmid: 17054564].
132 Carroll AE, Downs SM. Improving decision analyses: parent preferences (utility values) for pediatric health outcomes. Journal of Pediatrics. 2009;155(1):25.e1-5. 21. Ju. Off topic.
133 Cartwright RA. Problems and solutions for estimating indel rates and length distributions. Molecular Biology & Evolution. Feb. 2009;26(2):473-80. Off topic. [pmid: 19042944].
134 Cashin RP, Lui P, Machado M, et al. Advanced cutaneous malignant melanoma: a systematic review of economic and quality of life studies. Value in Health. Mar Apr. 2008;11(2):259. Review. [pmid: 18380638].
135 Castleberry AW, Smith D, Anderson C, et al. Cost of a 5-year lung cancer survivor: symptomatic tumour identification vs proactive computed tomography screening. British journal of cancer. Sep. 15. 2009;101(6):882. Cost Only. [pmid: 19690541].
136 Caulkins JP, Tragler G, Wallner D. Optimal timing of use reduction vs. harm reduction in a drug epidemic model. International Journal of Drug Policy. Nov. 2009;20(6):480-7. Off topic. [pmid: 19361975].
137 Cawley J. The cost effectiveness of programs to prevent or reduce obesity: the state of the literature and a future research agenda. Archives of Pediatrics & Adolescent Medicine. Jun. 2007;161(6):611. Off topic. [pmid: 17548770].
138 Chalkidou K. Comparative effectiveness review within the U.K.'s National Institute for Health and Clinical Excellence. Issue Brief (Commonwealth Fund). Jul. 2009;59:1. Off topic. [pmid: 19639713].
139 Chan AL, Leung HW, Lu CL, et al. Cost-effectiveness of trastuzumab as adjuvant therapy for early breast cancer: a systematic review. erratum appears in Ann Pharmacother. 2009 Mar;43(3):551. Annals of Pharmacotherapy. Feb. 2009;43(2):296. Review. [pmid: 19193576].
140 Chan ALF, Leung HWC, Lu CL, et al. Cost-effectiveness of trastuzumab as adjuvant therapy for early breast cancer: a systematic review. Annals of Pharmacotherapy. Feb. 2009;43(2):296-303. Review. [pmid: 19193576].
141 Chand S, Moskowitz H, Norris JB, et al. Improving patient flow at an outpatient clinic: study of sources of variability and improvement factors. Health Care Management Science. Sep. 2009;12(3):325-40. Off topic. [pmid: 19739363].
142 Chanda P, Masiye F, Chitah BM, et al. A cost effectiveness analysis of artemether lumefantrine for treatment of uncomplicated malaria in Zambia. Malaria Journal. 2007;6:21. Statistical Analysis. [pmid: 17313682].
143 Chang KY, Chan KH, Chang SH, et al. Decision analysis for epidural labor analgesia with Multiattribute Utility (MAU) model. Clinical Journal of Pain. Mar Apr. 2008;24(3):265. Off topic. [pmid: 18287834].
144 Chang VT, Cartwright PS, Bean SM, et al. Quantitative physiology of the precancerous cervix in vivo through optical spectroscopy. Neoplasia (New York). Apr. 2009;11(4):325. Off topic.
145 Chang WC, Lee MC, Yeh LS, et al. Quality initiated prophylactic antibiotic use in laparoscopic assisted vaginal hysterectomy. Australian & New Zealand Journal of Obstetrics & Gynaecology. Dec. 2008;48(6):592. Statistical analysis. [pmid: 19133050].
146 Chao TK, Chen THH. Predictive model for progression of hearing loss: meta-analysis of multi-state outcome. Journal of Evaluation in Clinical Practice. Feb. 2009;15(1):32-40. Off topic. [pmid: 19239579].
147 Chapman DP, Perry GS. Depression as a major component of public health for older adults. Preventing Chronic Disease. Jan. 2008;5(1):A22. Off topic. [pmid: 18082011].
148 Chen CW, Ju MS, Sun YN, et al. Model analyses of visual biofeedback training for EEG-based brain-computer interface. Journal of Computational Neuroscience. Dec. 2009;27(3):357-68. Off topic. [pmid: 19357940].
149 Chen LS, Liao CS, Chang SH, et al. Cost effectiveness analysis for determining optimal cut off of immunochemical faecal occult blood test for population based colorectal cancer screening (KCIS 16). Journal of medical screening. 2007;14(4):191. Statistical Analysis. [pmid: 18078564].
150 Chen NC, Shauver MJ, Chung KC. A primer on use of decision analysis methodology in hand surgery. Journal of Hand Surgery American Volume. Jul-Aug. 2009;34(6):983-90. Off topic.
151 Chen W, Kitazawa M, Togawa T. Estimation of the biphasic property in a female's menstrual cycle from cutaneous temperature measured during sleep. Annals of Biomedical Engineering. Sep. 2009;37(9):1827-38. Off topic. [pmid: 19551509].
152 Chen Y, Liu B, O'Connor JM, et al. Characterization of scatter in cone-beam CT breast imaging: comparison of experimental measurements and Monte Carlo simulation. Medical physics. Mar. 2009;36(3):857. Off topic. [pmid: 19378746].
153 Cheng BY, Carbonell JG, Klein-Seetharaman J. Protein classification based on text document classification techniques. Proteins. Mar. 1. 2005;58(4):955. Off topic. [pmid: 15645499].
154 Cheng JW. Pharmacoeconomic analysis of clopidogrel in secondary prevention of coronary artery disease. Journal of Managed Care Pharmacy. May. 2007;13(4):326. Review. [pmid: 17506599].
155 Cheng MM, Lu B, Hu SS, et al. Optimizing CAD diagnosis in China with CT angiography. Journal of cardiovascular computed tomography. May-Jun. 2009;3(3):153. Cost Only. [pmid: 19394919].
156 Cheung KJJ, Shah SP, Steidl C, et al. Genome-wide profiling of follicular lymphoma by array comparative genomic hybridization reveals prognostically significant DNA copy number imbalances. Blood. Jan. 1. 2009;113(1):137-48. Off topic. [pmid: 18703704].
157 Chiou CF, Weaver MR, Bell MA, et al. Development of the multi-attribute Pediatric Asthma Health Outcome Measure (PAHOM). International Journal for Quality in Health Care. Feb. 2005;17(1):23. Off topic. [pmid: 15668307].
158 Chiu E, Jeste DV. Efficacy and cost effectiveness in dementia interventions: the need for an international consensus. Current Opinion in Psychiatry. Nov. 2006;19(6):553. Cost only. [pmid: 17012930].
159 Cho DY, Tsao M, Lee WY, et al. Socioeconomic costs of open surgery and gamma knife radiosurgery for benign cranial base tumors. Neurosurgery. discussion 866-73. May. 2006;58(5):866. Statistical Analysis. [pmid: 16639320].
160 Chong CA, Tomlinson G, Chodirker L, et al. An unadjusted NNT was a moderately good predictor of health benefit. Journal of clinical epidemiology. Mar. 2006;59(3):224. Review. [pmid: 16488352].
161 Chouaid C, Atsou K, Hejblum G, et al. Economics of treatments for non-small cell lung cancer. PharmacoEconomics. 2009;27(2):113. Review. [pmid: 19254045].
162 Chow I, Lemos EV, Einarson TR. Management and prevention of diabetic foot ulcers and infections: a health economic review. PharmacoEconomics. 2008;26(12):1019. Review. [pmid: 19014203].
163 Chow JC. Calculation of lateral buildup ratio using Monte Carlo simulation for electron radiotherapy. Medical physics. Jan. 2007;34(1):175. Off topic. [pmid: 17278502].
164 Choy CK, Spencer AP, Nappi JM. Prevalence of anemia in clinic patients with heart failure and cost analysis of epoetin treatment. Pharmacotherapy. May. 2007;27(5):707. Cost Only. [pmid: 17461706].
165 Chu PC, Hwang JS, Wang JD, et al. Estimation of the financial burden to the National Health Insurance for patients with major cancers in Taiwan. Journal of the Formosan Medical Association. Jan. 2008;107(1):54. Costs only. [pmid: 18218578].
166 Claret L, Girard P, Hoff PM, et al. Model-based prediction of phase III overall survival in colorectal cancer on the basis of phase II tumor dynamics. Journal of Clinical Oncology. Sep. 1. 2009;27(25):4103-8. Decision aid. [pmid: 19636014].
167 Claxton K, Culyer AJ. Rights, responsibilities and NICE a rejoinder to Harris. Journal of medical ethics. Aug. 2007;33(8):462. Off topic. [pmid: 17664303].
168 Claxton K, Sculpher M, Culyer A, et al. Discounting and cost effectiveness in NICE stepping back to sort out a confusion. Health economics. Jan. 2006;15(1):1. Off topic. [pmid: 16365910].
169 Cleemput I, Thiry N. Cost-effectiveness evaluation of a quadrivalent human papillomavirus vaccine in Belgium. PharmacoEconomics. author reply 433-4. 2009;27(5):433. Other. [pmid: 19586082].
170 Clement Nee, Shrive FM, Ghali WA, Donaldson C, et al. The impact of using different costing methods on the results of an economic evaluation of cardiac care: microcosting vs gross-costing approaches. Health economics. Apr. 2009;18(4):377. Off topic. [pmid: 18615835].
171 Coca A. Economic benefits of treating high risk hypertension with angiotensin II receptor antagonists (blockers). Clinical Drug Investigation. 2008;28(4):211. Review. [pmid: 18345711].
172 Cockcroft PD. Clinical reasoning and decision analysis. Veterinary Clinics of North America Small Animal Practice. May. 2007;37(3):499. Off topic.
173 Cohen JH, Faughnan ME, Letarte M, et al. Cost comparison of genetic and clinical screening in families with hereditary hemorrhagic telangiectasia. American Journal of Medical Genetics.Part A. Aug. 30. 2005;137(2):153. Cost Only. [pmid: 16059938].
174 Cohen JT, Neumann PJ. Decision analytic models for Alzheimer's disease: state of the art and future directions. Alzheimer's & Dementia. May. 2008;4(3):212. Review.
175 Coleman CI, McKay RG, Boden WE, et al. Effectiveness and cost effectiveness of facilitated percutaneous coronary intervention compared with primary percutaneous coronary intervention in patients with ST segment elevation myocardial infarction transferred from community hospitals. Clinical therapeutics. Jul. 2006;28(7):1054. Statistical Analysis. [pmid: 16990084].
176 Collins CD, Ellis JJ, Kaul DR. Comparative cost effectiveness of posaconazole versus fluconazole or itraconazole prophylaxis in patients with prolonged neutropenia. American Journal of Health System Pharmacy. Dec. 1. 2008;65(23):2237. Costs only. [pmid: 19020192].
177 Cooper D, Moisan J, Abdous B, et al. A population based cost effectiveness analysis of olanzapine and risperidone among ambulatory patients with schizophrenia. Canadian Journal of Clinical Pharmacology/Journal Canadien de Pharmacologie Clinique. 2008;15(3):e385. Off topic.
178 Cooper K, Brailsford SC, Davies R, et al. A review of health care models for coronary heart disease interventions. Health care management science. Nov. 2006;9(4):311. Review. [pmid: 17186767].
179 Cooper K, Bryant J, Picot J, et al. A decision analysis model for diagnostic strategies using DNA testing for hereditary haemochromatosis in at risk populations. Qjm. Aug. 2008;101(8):631. Costs only. [pmid: 18522976].
180 Cornes P, Coiffier B, Zambrowski JJ. Erythropoietic therapy for the treatment of anemia in patients with cancer: a valuable clinical and economic option. Current Medical Research & Opinion. Feb. 2007;23(2):357. Review. [pmid: 17288690].
181 Corso PS, Edwards VJ, Fang X, et al. Health related quality of life among adults who experienced maltreatment during childhood. American Journal of Public Health. Jun. 2008;98(6):1094. Statistical analysis. [pmid: 18445797].
182 Costa-Scharplatz M, Ramanathan K, Frial T, et al. Cost effectiveness analysis of rosuvastatin versus atorvastatin, simvastatin, and pravastatin from a Canadian health system perspective. Clinical therapeutics. Jul. 2008;30(7):1345. Statistical analysis. [pmid: 18691996].
183 Coupe VM, Veenhof C, van Tulder MW, et al. The cost effectiveness of behavioural graded activity in patients with osteoarthritis of hip and/or knee. Annals of the Rheumatic Diseases. Feb. 2007;66(2):215. Statistical Analysis. [pmid: 16880195].
184 Cowans NJ, Stamatopoulou A, Maiz N, et al. The impact of fetal gender on first trimester nuchal translucency and maternal serum free beta-hCG and PAPP-A MoM in normal and trisomy 21 pregnancies. Prenatal Diagnosis. Jun. 2009;29(6):578-81. Statistical anlaysis. [pmid: 19288535].
185 Cronin KA, Miglioretti DL, Krapcho M, et al. Bias associated with self-report of prior screening mammography. Cancer Epidemiology, Biomarkers & Prevention. Jun. 2009;18(6):1699-705. Off topic.
186 Cross WW 3rd, Saleh KJ, Wilt TJ, et al. Agreement about indications for total knee arthroplasty. Clinical Orthopaedics & Related Research. May. 2006;446:34. Off topic. [pmid: 16672869].
187 Culyer A, McCabe C, Briggs A, et al. Searching for a threshold, not setting one: the role of the National Institute for Health and Clinical Excellence. Journal of Health Services & Research Policy. Jan. 2007;12(1):56. Off topic.
188 da Luz Moreira A, Stocchi L, Tan E, et al. Outcomes of Crohn's disease presenting with abdominopelvic abscess. Diseases of the Colon & Rectum. May. 2009;52(5):906. Off topic. [pmid: 19502855].
189 da Silveira E. Cost effectiveness of screening for HIV. New England Journal of Medicine. author reply 2137-9. May. 19. 2005;352(20):2137. Cost only. [pmid: 15906436].
190 Dagenais S, Haldeman S, Polatin PB. It is time for physicians to embrace cost effectiveness and cost utility analysis research in the treatment of spinal pain. Spine Journal: Official Journal of the North American Spine Society. Jul-Aug. 2005;5(4):357. Cost only.
191 Dale W, Basu A, Elstein A, et al. Predicting utility ratings for joint health States from single health States in prostate cancer: empirical testing of 3 alternative theories. Medical Decision Making. Jan Feb. 2008;28(1):102. Off topic. [pmid: 18057188].
192 Dall TM, Fulgoni VL 3rd, Zhang Y, et al. Predicted national productivity implications of calorie and sodium reductions in the American diet. American Journal of Health Promotion. Jul-Aug. 2009;23(6):423-30. Off topic. [pmid: 19601482].
193 Dall TM, Fulgoni VL 3rd, Zhang Y, et al. Potential health benefits and medical cost savings from calorie, sodium, and saturated fat reductions in the American diet. American Journal of Health Promotion. Jul-Aug. 2009;23(6):412-22. Off topic. [pmid: 19601481].
194 Danish SF, Barone D, Lega BC, et al. Quality of life after hemicraniectomy for traumatic brain injury in adults. A review of the literature. Neurosurgical Focus. Jun. 2009;26(6):E2. Review. [pmid: 19485715].
195 Darlington AS, Dippel DW, Ribbers GM, et al. A prospective study on coping strategies and quality of life in patients after stroke, assessing prognostic relationships and estimates of cost-effectiveness. Journal of Rehabilitation Medicine. Mar. 2009;41(4):237. Statistical Analysis. [pmid: 19247542].
196 Darmon P, Lochs H, Pichard C. Economic impact and quality of life as endpoints of nutritional therapy. Current Opinion in Clinical Nutrition & Metabolic Care. Jul. 2008;11(4):452. Off topic. [pmid: 18542006].
197 Dasbach EJ, Elbasha EH, Insinga RP. Mathematical models for predicting the epidemiologic and economic impact of vaccination against human papillomavirus infection and disease. Epidemiologic reviews. 2006;28:88. Review. [pmid: 16740585].
198 Davis GE, Schwartz SR, Veenstra DL, et al. Cost comparison of surgery vs organ preservation for laryngeal cancer. Archives of Otolaryngology Head & Neck Surgery. Jan. 2005;131(1):21. Cost Only. [pmid: 15655180].
199 Dayton JD, Kanter KR, Vincent RN, et al. Cost effectiveness of pediatric heart transplantation. Journal of Heart & Lung Transplantation. Apr. 2006;25(4):409. Statistical Analysis. [pmid: 16563970].
200 de Leon JM, Barnes S, Nagel M, et al. Cost-effectiveness of negative pressure wound therapy for postsurgical patients in long-term acute care. Advances in Skin & Wound Care. Mar. 2009;22(3):122-7. Off topic. [pmid: 19247013].
201 de Nazelle A, Rodriguez DA, Crawford-Brown D. The built environment and health: impacts of pedestrian-friendly designs on air pollution exposure. Science of the Total Environment. Apr. 1. 2009;407(8):2525-35. Off topic. [pmid: 19201451].
202 de Zee M, Cattaneo PM, Svensson P, et al. Prediction of the articular eminence shape in a patient with unilateral hypoplasia of the right mandibular ramus before and after distraction osteogenesis-A simulation study. Journal of Biomechanics. May. 29. 2009;42(8):1049-53. Off topic. [pmid: 19356762].
203 Dendukuri N, Khetani K, McIsaac M, et al. Testing for HER2 positive breast cancer: a systematic review and cost effectiveness analysis. CMAJ Canadian Medical Association Journal. May. 8. 2007;176(10):1429. Review.
204 Deng X, Wang X, Liu H, et al. Simulation study of second harmonic microscopic imaging signals through tissue like turbid media. Journal of Biomedical Optics. Mar-Apr. 2006;11(2):024013. Off topic. [pmid: 16674203].
205 Dennett SL, Boye KS, Yurgin NR. The impact of body weight on patient utilities with or without type 2 diabetes: a review of the medical literature. Value in Health. May Jun. 2008;11(3):478. Review. [pmid: 18489671].
206 Derrett S, Stokes EA, James M, et al. Cost and health status analysis after autologous chondrocyte implantation and mosaicplasty: a retrospective comparison. International Journal of Technology Assessment in Health Care. 2005;21(3):359. Statistical Analysis. [pmid: 16110716].
207 DeSantis SM, Bandyopadhyay D, Back SE, et al. Non-treatment laboratory stress- and cue-reactivity studies are associated with decreased substance use among drug-dependent individuals. Drug & Alcohol Dependence. Dec. 1. 2009;105(3):227-33. Statistical analysis. [pmid: 19717245].
208 Deshpande O, Batzoglou S, Feldman MW, et al. A serial founder effect model for human settlement out of Africa. Proceedings of the Royal Society of London Series B: Biological Sciences. Jan. 22. 2009;276(1655):291-300. Off topic.
209 Deuffic-Burban S, Mathurin P, Valleron AJ. Modelling the past, current and future HCV burden in France: detailed analysis and perspectives. Statistical Methods in Medical Research. Jun. 2009;18(3):233-52. Off topic. [pmid: 19036916].
210 Dhainaut JF, Payet S, Vallet B, et al. Cost effectiveness of activated protein C in real life clinical practice. Critical care (London, England). 2007;11(5):R99. Statistical Analysis.
211 Dhillon S, Lyseng-Williamson KA. Zoledronic acid : a review of its use in the management of bone metastases of malignancy. Drugs. 2008;68(4):507. Review. [pmid: 18318568].
212 Diaz JH. A decision analysis model to justify and approve off label drug use in pain and palliative care. Pain Practice. May Jun. 2008;8(3):153. No abstract. [pmid: 18476893].
213 Diel R, Nienhaus A, Lange C, et al. Cost optimisation of screening for latent tuberculosis in close contacts. European Respiratory Journal. Jul. 2006;28(1):35. Off topic. [pmid: 16571615].
214 Dijkgraaf MG, van der Zanden BP, de Borgie CA, et al. Cost utility analysis of co prescribed heroin compared with methadone maintenance treatment in heroin addicts in two randomised trials. BMJ. Jun. 4. 2005;330(7503):1297. Statistical Analysis. [pmid: 15933353].
215 Dinh P, Zhou XH. Nonparametric statistical methods for cost effectiveness analyses. Biometrics. Jun. 2006;62(2):576. Statistical Analysis. [pmid: 16918923].
216 Dixon S, Walker M, Salek S. Incorporating carer effects into economic evaluation. PharmacoEconomics. 2006;24(1):43. Off topic. [pmid: 16445302].
217 Doan QV, Chiou CF, Dubois RW. Review of eight pharmacoeconomic studies of the value of biologic DMARDs (adalimumab, etanercept, and infliximab) in the management of rheumatoid arthritis. Journal of Managed Care Pharmacy. Sep. 2006;12(7):555. Review. [pmid: 16981801].
218 Dodson JA, Horn EM, Dickstein M, et al. Physiologic determinants of mitral inflow pattern using a computer simulation: insights into Doppler echocardiography in diverse phenotypes. Echocardiography. Feb. 2009;26(2):155-62. Off topic. [pmid: 19207994].
219 Doggrell SA. CLARITY about the use of clopidogrel in patients with acute coronary syndromes and myocardial infarction. Expert opinion on pharmacotherapy. Aug. 2005;6(10):1761. Review. [pmid: 16086662].
220 Dolan JG. Patient priorities in colorectal cancer screening decisions. Health Expectations. Dec. 2005;8(4):334. Off topic. [pmid: 16266421].
221 Dolan P, Shaw R, Tsuchiya A, et al. QALY maximisation and people's preferences: a methodological review of the literature. Health economics. Feb. 2005;14(2):197. Off topic. [pmid: 15386656].
222 Donnan PT, McLernon D, Dillon JF, et al. Development of a decision support tool for primary care management of patients with abnormal liver function tests without clinically apparent liver disease: a record-linkage population cohort study and decision analysis (ALFIE). Health technology assessment (Winchester, England). 1. 134. Apr. 2009;13(25):ix-xi. iii. Statistical Analysis.
223 Donnan PT, McLernon D, Dillon JF, et al. Development of a decision support tool for primary care management of patients with abnormal liver function tests without clinically apparent liver disease: a record-linkage population cohort study and decision analysis (ALFIE). Health Technology Assessment (Winchester, England). Apr. 2009;13(25):iii-iv. 1. 134. Decision aid.
224 Donohue JM, Pincus HA. Reducing the societal burden of depression: a review of economic costs, quality of care and effects of treatment. PharmacoEconomics. 2007;25(1):7. Off topic. [pmid: 17192115].
225 Dooms CA, Lievens YN, Vansteenkiste JF. Cost utility analysis of chemotherapy in symptomatic advanced nonsmall cell lung cancer. European Respiratory Journal. May. 2006;27(5):895. Statistical Analysis. [pmid: 16481384].
226 Dowding CH, Shenton CL, Salek SS. A review of the health related quality of life and economic impact of Parkinson's disease. Drugs & aging. 2006;23(9):693. Off topic. [pmid: 17020395].
227 Dretzke J, Frew E, Davenport C, et al. The effectiveness and cost effectiveness of parent training/education programmes for the treatment of conduct disorder, including oppositional defiant disorder, in children. Health technology assessment (Winchester, England). 1. 233. Dec. 2005;9(50):ix-x. iii. ix. Review.
228 Dreyfuss JH. Simulation model predicts cost savings from colorectal cancer screening. CA: a Cancer Journal for Clinicians. Jan-Feb. 2010;60(1):3-5. No abstract. [pmid: 20018975].
229 Drovandi CC, Pettitt AN. Multivariate Markov process models for the transmission of methicillin resistant Staphylococcus aureus in a hospital ward. Biometrics. Sep. 2008;64(3):851. Off topic. [pmid: 18047536].
230 Drummond M, Manca A, Sculpher M. Increasing the generalizability of economic evaluations: recommendations for the design, analysis, and reporting of studies. International Journal of Technology Assessment in Health Care. 2005;21(2):165. Off topic. [pmid: 15921055].
231 Drummond MF, Iglesias CP, Cooper NJ. Systematic reviews and economic evaluations conducted for the National Institute for Health and Clinical Excellence in the United Kingdom: a game of two halves?. International Journal of Technology Assessment in Health Care. 2008;24(2):146. Review. [pmid: 18400116].
232 Dubnov J, Hefer E, Rubin L, et al. A change in rabies post exposure treatment guidelines after decision analysis in Israel. European journal of public health. Feb. 2007;17(1):92. Statistical Analysis. [pmid: 16837519].
233 Ducote JL, Molloi S. Quantification of breast density with dual energy mammography: a simulation study. Medical physics. Dec. 2008;35(12):5411. Off topic. [pmid: 19175100].
234 Duh MS, Weiner JR, White LA, et al. Management of anaemia: a critical and systematic review of the cost effectiveness of erythropoiesis stimulating agents. PharmacoEconomics. 2008;26(2):99. Review. [pmid: 18198931].
235 Duintjer Tebbens RJ, Pallansch MA, Kew OM, et al. Uncertainty and sensitivity analyses of a decision analytic model for posteradication polio risk management. Risk Analysis. Aug. 2008;28(4):855. Off topic. [pmid: 18627544].
236 Dunbar JA, Hsu V, Christensen M, et al. Cost-utility analysis of screening and laser treatment of retinopathy of prematurity. Journal of Aapos: American Association for Pediatric Ophthalmology & Strabismus. Apr. 2009;13(2):186. Off topic.
237 Dundar Y, Bagust A, Hounsome J, et al. Rituximab for the first-line treatment of stage III/IV follicular non-Hodgkin's lymphoma. Health technology assessment (Winchester, England). Jun. 2009;13(Suppl 1):23. Review.
238 Dunn C, Keam SJ. Letrozole: a pharmacoeconomic review of its use in postmenopausal women with breast cancer. PharmacoEconomics. 2006;24(5):495. Review. [pmid: 16706574].
239 Dutheil JY, Ganapathy G, Hobolth A, et al. Ancestral population genomics: the coalescent hidden Markov model approach. Genetics. Sep. 2009;183(1):259-74. Off topic. [pmid: 19581452].
240 Earnshaw SR, Wilson MR, Joshi AV. The effect of recombinant activated factor VII in the treatment of intracerebral hemorrhage on health plan budgets. Managed care interface. Nov. 2006;19(11):39. Cost Only. [pmid: 17137241].
241 Ebels T, Maruszewski B, Blackstone EH. What is the preferred therapy for patients with aortic coarctation the standard gamble and decision analysis versus real results?. Cardiology in the young. Feb. 2008;18(1):18. No abstract. [pmid: 18093361].
242 Ebersberger I, Strauss S, von Haeseler A. HaMStR: profile hidden markov model based search for orthologs in ESTs. BMC Evolutionary Biology. 2009;9:157. Off topic. [pmid: 19586527].
243 Egi M, Bellomo R, Stachowski E, et al. Intensive insulin therapy in postoperative intensive care unit patients: a decision analysis. American Journal of Respiratory & Critical Care Medicine. Feb. 15. 2006;173(4):407. Off topic. [pmid: 16239623].
244 Eijkemans GJ, Takala J. Moving knowledge of global burden into preventive action. American Journal of Industrial Medicine. Dec. 2005;48(6):395. Off topic. [pmid: 16299702].
245 Einarson TR, Granton JT, Vicente C, et al. Cost effectiveness of treprostinil versus epoprostenol in patients with pulmonary arterial hypertension: a Canadian analysis. Canadian Respiratory Journal. Nov-Dec. 2005;12(8):419. Cost Only. [pmid: 16331313].
246 Einstein AJ, Henzlova MJ, Rajagopalan S. Estimating risk of cancer associated with radiation exposure from 64 slice computed tomography coronary angiography. Jama. Jul. 18. 2007;298(3):317. Off topic. [pmid: 17635892].
247 Eisenberg M, Distefano JJ. TSH-based protocol, tablet instability, and absorption effects on L-T4 bioequivalence. Thyroid. Feb. 2009;19(2):103-10. Off topic. [pmid: 19191742].
248 Ekwueme DU, Hall IJ, Richardson LC, et al. Estimating personal costs incurred by a woman participating in mammography screening in the National Breast and Cervical Cancer Early Detection Program. Cancer. Aug. 1. 2008;113(3):592. Off topic. [pmid: 18536027].
249 Elbasha EH. Risk aversion and uncertainty in cost effectiveness analysis: the expected utility, moment generating function approach. Health economics. May. 2005;14(5):457. Off topic. [pmid: 15386661].
250 Elkin EB, Vickers AJ, Kattan MW. Primer: using decision analysis to improve clinical decision making in urology. Nature Clinical Practice Urology. Aug. 2006;3(8):439. Off topic.
251 Elnitsky CA, Stone P. Patient preferences and cost utility analysis. Applied Nursing Research. May. 2005;18(2):74. Off topic. [pmid: 15991103].
252 Emmett CL, Montgomery AA, Peters TJ, et al. Three year follow up of a factorial randomised controlled trial of two decision aids for newly diagnosed hypertensive patients. British Journal of General Practice. Jul. 2005;55(516):551. Review. [pmid: 16004744].
253 Emmett CL, Murphy DJ, Patel RR, et al. Decision making about mode of delivery after previous caesarean section: development and piloting of two computer based decision aids. Health Expectations. Jun. 2007;10(2):161. Off topic. [pmid: 17524009].
254 Emmez H, Kucukoduk I, Borcek AO, et al. Effectiveness of skull models and surgical simulation: comparison of outcome between different surgical techniques in patients with isolated brachycephaly. Childs Nervous System. Dec. 2009;25(12):1605-12. Off topic.
255 Epstein DM, Chalabi Z, Claxton K, et al. Efficiency, equity, and budgetary policies: informing decisions using mathematical programming. Medical Decision Making. Mar Apr. 2007;27(2):128. Off topic. [pmid: 17409363].
256 Eriksson P. Creative cost effectiveness analysis of CAPRIE data dust in our eyes. American Journal of Medicine. author reply 200. Feb. 2005;118(2):199. Cost only. [pmid: 15694910].
257 Ernst R. Indirect costs and cost effectiveness analysis. Value in Health. Jul-Aug. 2006;9(4):253. Off topic. [pmid: 16903995].
258 Evans J, Lipp A. Health economics: what value to the theatre practitioner?. Journal of Perioperative Practice. Mar. 2009;19(3):88. Off topic. [pmid: 19397059].
259 Extermann M. Decision analysis for cancer prevention and cancer treatment in the elderly. Cancer Treatment & Research. 2005;124:223. Cost only. [pmid: 15839198].
260 Fagnoni P, Limat S, Chaigneau L, et al. Clinical and economic impact of epoetin in adjuvant chemotherapy for breast cancer. Supportive Care in Cancer. Oct. 2006;14(10):1030. Statistical Analysis. [pmid: 16802128].
261 Falagas ME, Kazantzi MS, Bliziotis IA. Comparison of utility of blood cultures from intravascular catheters and peripheral veins: a systematic review and decision analysis. Journal of medical microbiology. Jan. 2008;57(Pt 1):1. Off topic. [pmid: 18065660].
262 Fang CT, Chang YY, Hsu HM, et al. Life expectancy of patients with newly diagnosed HIV infection in the era of highly active antiretroviral therapy. Qjm. Feb. 2007;100(2):97. Statistical Analysis. [pmid: 17277317].
263 Farley FA, Kramer J, Watkins-Castillo S. Work satisfaction and retirement plans of orthopaedic surgeons 50 years of age and older. Clinical Orthopaedics & Related Research. Jan. 2008;466(1):231. Off topic. [pmid: 18196399].
264 Farrell KB, Tusnady GE, Eiden MV. New structural arrangement of the extracellular regions of the phosphate transporter SLC20A1, the receptor for gibbon ape leukemia virus. Journal of Biological Chemistry. Oct. 23. 2009;284(43):29979-87. Off topic. [pmid: 19717569].
265 Fauchier L, Babuty D. Cost effectiveness of ICDs. New England Journal of Medicine. author reply 205-7. Jan. 12. 2006;354(2):205. Cost only. [pmid: 16411302].
266 Felli JC, Noel RA, Cavazzoni PA. A multiattribute model for evaluating the benefit-risk profiles of treatment alternatives. Medical Decision Making. Jan-Feb. 2009;29(1):104. Off topic. [pmid: 18812582].
267 Fennerty MB. Helicobacter pylori: why it still matters in 2005. Cleveland Clinic journal of medicine. discussion S14-21. May. 2005;72(Suppl 2):S1. Off topic. [pmid: 15931849].
268 Fenwick MK, Escobedo FA. Exploration of factors affecting the onset and maturation course of follicular lymphoma through simulations of the germinal center. Bulletin of Mathematical Biology. Aug. 2009;71(6):1432-62. Off topic. [pmid: 19412639].
269 Ferko N, Postma M, Gallivan S, et al. Evolution of the health economics of cervical cancer vaccination. Vaccine. Sep. 15. 2008;26(Suppl 5):F3. Review. [pmid: 18992381].
270 Fesinmeyer MD, Gulati R, Zeliadt S, et al. Effect of population trends in body mass index on prostate cancer incidence and mortality in the United States. Cancer Epidemiology, Biomarkers & Prevention. Mar. 2009;18(3):808-15. Off topic.
271 Fevre EM, Odiit M, Coleman PG, et al. Estimating the burden of rhodesiense sleeping sickness during an outbreak in Serere, eastern Uganda. BMC Public Health. 2008;8:96. Off topic. [pmid: 18366755].
272 Fiedler JL, Chuko T. The cost of Child Health Days: a case study of Ethiopia's Enhanced Outreach Strategy (EOS). Health Policy & Planning. Jul. 2008;23(4):222. Off topic. [pmid: 18562457].
273 Filion KB, Roy AM, Baboushkin T, et al. Cost-effectiveness of drug-eluting stents including the economic impact of late stent thrombosis. American Journal of Cardiology. Feb. 1. 2009;103(3):338. Review. [pmid: 19166686].
274 Finn RD, Mistry J, Tate J, et al. The Pfam protein families database. Nucleic Acids Research. Jan. 2010;38(Database issue):D211-22. Off topic. [pmid: 19920124].
275 First MB. Reorganizing the diagnostic groupings in DSM-V and ICD-11: a cost/benefit analysis. Psychological Medicine. Dec. 2009;39(12):2091-7. No abstract. [pmid: 19796432].
276 Fitzgerald TS, Prieve BA. Detection of hearing loss using 2f2 f1 and 2f1 f2 distortion product otoacoustic emissions. Journal of Speech Language & Hearing Research. Oct. 2005;48(5):1165. Off topic.
277 Fleige LE, Sahyoun NR, Murphy SP. A new simulation model estimates micronutrient levels to include in fortified blended foods used in food aid programs. Journal of Nutrition. Feb. 2010;140(2):355-65. Off topic. [pmid: 20007339].
278 Flemmig TF, Beikler T. Decision making in implant dentistry: an evidence-based and decision-analysis approach. Periodontology 2000. 2009;50:154. Other. [pmid: 19388958].
279 Fleurence R, Spackman E. Cost effectiveness of biologic agents for treatment of autoimmune disorders: structured review of the literature. Journal of Rheumatology. Nov. 2006;33(11):2124. Review. [pmid: 17086602].
280 Forbes R. Cost utility of vagus nerve stimulation (VNS) therapy for medically refractory epilepsy an update. Seizure. Jun. 2008;17(4):387. No abstract. [pmid: 18584780].
281 Force USPST. Annals of Internal Medicine. Nov. 4. 2008;149(9):627. Off topic. [pmid: 18838716].
282 Forgione A, Leroy J, Cahill RA, et al. Prospective evaluation of functional outcome after laparoscopic sigmoid colectomy. Annals of Surgery. Feb. 2009;249(2):218. Off topic. [pmid: 19212173].
283 Franco OH, Peeters A, Looman CW, et al. Cost effectiveness of statins in coronary heart disease. Journal of Epidemiology & Community Health. Nov. 2005;59(11):927. Review. [pmid: 16234419].
284 Franco OH, Steyerberg EW, Peeters A, et al. Effectiveness calculation in economic analysis: the case of statins for cardiovascular disease prevention. Journal of Epidemiology & Community Health. Oct. 2006;60(10):839. Review. [pmid: 16973528].
285 Freed MC, Rohan KJ, Yates BT. Estimating health utilities and quality adjusted life years in seasonal affective disorder research. Journal of affective disorders. Jun. 2007;100(1 3):83. Statistical Analysis. [pmid: 17084462].
286 Frick KD, Massof RW. Use of Global Visual Acuity Data in a time trade-off approach to calculate the cost utility of cataract surgery: methodological issues of cost-utility comparisons. Archives of Ophthalmology. Sep. 2009;127(9):1205. Other. [pmid: 19752432].
287 Fritscher L, Chapman KR. Seretide: a pharmacoeconomic analysis. Journal of Medical Economics. 2008;11(3):555. Off topic. [pmid: 19450105].
288 Fronstin P, Salisbury D, VanDerhei J. Savings needed to fund health insurance and health care expenses in retirement: findings from a simulation model. EBRI Issue Brief. May. 2008;(317):4-27. 1. Off topic.
289 Frost J, Shaw A, Montgomery A, et al. Women's views on the use of decision aids for decision making about the method of delivery following a previous caesarean section: qualitative interview study. BJOG: An International Journal of Obstetrics & Gynaecology. Jun. 2009;116(7):896. Off topic. [pmid: 19385964].
290 Fu HY, Xue DY, Zhang Xd, et al. Assessing potential miRNA targets based on a Markov model. Genetics & Molecular Research. 2009;8(3):848-60. Off topic. [pmid: 19731207].
291 Gafni A, Walter SD, Birch S, et al. An opportunity cost approach to sample size calculation in cost effectiveness analysis. Health economics. Jan. 2008;17(1):99. Off topic. [pmid: 17497751].
292 Gagnon A, Wilson RD, Allen VM, et al. Evaluation of prenatally diagnosed structural congenital anomalies. Journal of Obstetrics & Gynaecology Canada: JOGC. Sep. 2009;31(9):875-81. Decision aid.
293 Gandjour A. Incorporating feelings related to the uncertainty about future health in utility measurement. Health economics. Oct. 2008;17(10):1207. Off topic. [pmid: 18074407].
294 Gandjour A, Lauterbach KW. Does prevention save costs? Considering deferral of the expensive last year of life. Journal of health economics. Jul. 2005;24(4):715. Off topic. [pmid: 15960993].
295 Gandjour A, Lauterbach KW. How much does it cost to change the behavior of health professionals? A mathematical model and an application to academic detailing. Medical Decision Making. May-Jun. 2005;25(3):341. Off topic. [pmid: 15951461].
296 Garland SM, Cuzick J, Domingo EJ, et al. Recommendations for cervical cancer prevention in Asia Pacific. Vaccine. Aug. 19. 2008;26(Suppl 12):M89. Off topic. [pmid: 18945418].
297 Garnock-Jones KP, Keating GM. Atomoxetine: a review of its use in attention-deficit hyperactivity disorder in children and adolescents. Paediatric drugs. 2009;11(3):203. Off topic. [pmid: 19445548].
298 Garrison KR, Donell S, Ryder J, et al. Clinical effectiveness and cost effectiveness of bone morphogenetic proteins in the non healing of fractures and spinal fusion: a systematic review. Health technology assessment (Winchester, England). Aug. 2007;11(30):iii-iv. 1. Review.
299 Garvin R, Howard E. Are major bleeding events from falls more likely in patients on warfarin?. Journal of Family Practice. discussion 159. Feb. 2006;55(2):159. Off topic. [pmid: 16451785].
300 Gazelle GS, McMahon PM, Siebert U, et al. Cost effectiveness analysis in the assessment of diagnostic imaging technologies. Radiology. May. 2005;235(2):361. Off topic. [pmid: 15858079].
301 Gaziano TA. Economic burden and the cost effectiveness of treatment of cardiovascular diseases in Africa. Heart. Feb. 2008;94(2):140. Off topic. [pmid: 18195120].
302 Geiger D, Meek C, Wexler Y. Speeding up HMM algorithms for genetic linkage analysis via chain reductions of the state space. Bioinformatics. Jun. 15. 2009;25(12):i196-203. Off topic. [pmid: 19477987].
303 Gerla V, Paul K, Lhotska L, et al. Multivariate analysis of full-term neonatal polysomnographic data. IEEE Transactions on Information Technology in Biomedicine. Jan. 2009;13(1):104-10. Off topic. [pmid: 19129029].
304 Gerlach H, Toussaint S. Between prediction, education, and quality control: simulation models in critical care. Critical care (London, England). 2007;11(4):146. Off topic.
305 Gerzeli S, Torbica A, Fattore G. Cost utility analysis of knee prosthesis with complete microprocessor control (C-leg) compared with mechanical technology in trans-femoral amputees. European Journal of Health Economics. Feb. 2009;10(1):47. Off topic. [pmid: 18379831].
306 Getsios D, El-Hadi W, Caro I, et al. Pharmacological management of overactive bladder : a systematic and critical review of published economic evaluations. PharmacoEconomics. 2005;23(10):995. Review. [pmid: 16235973].
307 Ghori AK, Chung KC. A decision analysis model to diagnose feigned hand weakness. Journal of Hand Surgery American Volume. Dec. 2007;32(10):1638. Off topic.
308 Gil JM, Rubio-Terres C, Del Castillo A, et al. Pharmacoeconomic analysis of adjuvant therapy with exemestane, anastrozole, letrozole or tamoxifen in postmenopausal women with operable and estrogen receptor positive breast cancer. Clinical & Translational Oncology: Official Publication of the Federation of Spanish Oncology Societes & of the National Cancer Institute of Mexico. May. 2006;8(5):339. Cost only.
309 Gilbert FJ. Breast cancer screening in high risk women. Cancer Imaging. 2008;8(Suppl A):S6. Off topic. [pmid: 18852075].
310 Gilbody S, Bower P, Whitty P. Costs and consequences of enhanced primary care for depression: systematic review of randomised economic evaluations. British Journal of Psychiatry. Oct. 2006;189:297. Review. [pmid: 17012652].
311 Gillespie EL, White CM, Kluger J, et al. Cost effectiveness of amiodarone for prophylaxis of atrial fibrillation after cardiothoracic surgery. Pharmacotherapy. Apr. 2006;26(4):499. Statistical Analysis. [pmid: 16553508].
312 Gillespie EL, White CM, Kluger J, et al. A hospital perspective on the cost effectiveness of beta blockade for prophylaxis of atrial fibrillation after cardiothoracic surgery. Clinical therapeutics. Dec. 2005;27(12):1963. Statistical Analysis. [pmid: 16507383].
313 Gino F, Ayal S, Ariely D. Contagion and differentiation in unethical behavior: the effect of one bad apple on the barrel. Psychological Science. Mar. 2009;20(3):393-8. Off topic. [pmid: 19254236].
314 Girling AJ, Freeman G, Gordon JP, et al. Modeling payback from research into the efficacy of left ventricular assist devices as destination therapy. International Journal of Technology Assessment in Health Care. 2007;23(2):269. Statistical Analysis. [pmid: 17493314].
315 Girzadas DV Jr., Antonis MS, Zerth H, et al. Hybrid simulation combining a high fidelity scenario with a pelvic ultrasound task trainer enhances the training and evaluation of endovaginal ultrasound skills. Academic Emergency Medicine. May. 2009;16(5):429-35. Off topic. [pmid: 19388924].
316 Glassock RJ. Prophylactic anticoagulation in nephrotic syndrome: a clinical conundrum. Journal of the American Society of Nephrology. Aug. 2007;18(8):2221. Review. [pmid: 17599972].
317 Glazner JE, Beaty B, Berman S. Cost of vaccine administration among pediatric practices. Pediatrics. Dec. Suppl 5. 2009;124:S492-8. Off topic. [pmid: 19948580].
318 Glenngard AH, Persson U, Schon S. Cost effectiveness analysis of treatment with epoietin alpha for patients with anaemia due to renal failure: the case of Sweden. Scandinavian Journal of Urology & Nephrology. 2008;42(1):66. Review. [pmid: 17907051].
319 Godfrey C, Parrott S, Coleman T, et al. The cost effectiveness of the English smoking treatment services: evidence from practice. Addiction. Apr. 2005;100(Suppl 2):70. Statistical Analysis. [pmid: 15844290].
320 Goel R, Misra A, Kondal D, et al. Identification of insulin resistance in Asian Indian adolescents: classification and regression tree (CART) and logistic regression based classification rules. Clinical endocrinology. May. 2009;70(5):717. Statistical Analysis. [pmid: 18778399].
321 Goetghebeur MM, Wagner M, Khoury H, et al. Evidence and Value: Impact on DEcisionMaking the EVIDEM framework and potential applications. BMC Health Services Research. 2008;8:270. Off topic. [pmid: 19102752].
322 Gohler A, Geisler BP, Manne JM, et al. Utility estimates for decision-analytic modeling in chronic heart failure--health states based on New York Heart Association classes and number of rehospitalizations. Value in Health. Jan. 2009;12(1):185-7. Statistical analysis. [pmid: 18647251].
323 Goldberg JH. Being there is important, but getting there matters too: the role of path in the valuation process. Medical Decision Making. Jul-Aug. 2006;26(4):323. Off topic. [pmid: 16855122].
324 Goldberger Z, Elbel B, McPherson CA, et al. Cost advantage of dual chamber versus single chamber cardioverter defibrillator implantation. Journal of the American College of Cardiology. Sep. 6. 2005;46(5):850. Cost Only. [pmid: 16139136].
325 Golder S, Glanville J, Ginnelly L. Populating decision analytic models: the feasibility and efficiency of database searching for individual parameters. International Journal of Technology Assessment in Health Care. 2005;21(3):305. Off topic. [pmid: 16110709].
326 Goldman J. Is imatinib a cost effective treatment for newly diagnosed chronic myeloid leukemia patients?. Nature Clinical Practice Oncology. Mar. 2005;2(3):126. Cost only.
327 Goldman L. Cost effectiveness in a flat world can ICDs help the United States get rhythm?. New England Journal of Medicine. Oct. 6. 2005;353(14):1513. Cost only. [pmid: 16207856].
328 Gollan TH, Ferreira VS. Should I stay or should I switch? A cost-benefit analysis of voluntary language switching in young and aging bilinguals. Journal of Experimental Psychology: Learning, Memory, & Cognition. May. 2009;35(3):640-65. Off topic.
329 Gollust SE, Schroeder SA, Warner KE. Helping smokers quit: understanding the barriers to utilization of smoking cessation services. Milbank Quarterly. Dec. 2008;86(4):601. Off topic. [pmid: 19120982].
330 Gomez M, Bielza C, Fernandez del Pozo JA, et al. A graphical decision theoretic model for neonatal jaundice. Medical Decision Making. May Jun. 2007;27(3):250. Decision aid. [pmid: 17545496].
331 Gomollon F, Garcia Lopez S. Are we giving azathioprine too much time?. World Journal of Gastroenterology. Sep. 28. 2008;14(36):5519. Review. [pmid: 18810769].
332 Gordon L, Graves N, Hawkes A, et al. A review of the cost effectiveness of face to face behavioural interventions for smoking, physical activity, diet and alcohol. Chronic Illness. Jun. 2007;3(2):101. Review. [pmid: 18083667].
333 Gosselin RA, Heitto M. Cost effectiveness of a district trauma hospital in Battambang, Cambodia. World journal of surgery. Nov. 2008;32(11):2450. Off topic. [pmid: 18716830].
334 Gosselin RA, Thind A, Bellardinelli A. Cost/DALY averted in a small hospital in Sierra Leone: what is the relative contribution of different services?. World journal of surgery. Apr. 2006;30(4):505. Statistical Analysis. [pmid: 16528459].
335 Gould E. Childhood lead poisoning: conservative estimates of the social and economic benefits of lead hazard control. Environmental Health Perspectives. Jul. 2009;117(7):1162-7. Off topic. [pmid: 19654928].
336 Graf J, Wagner J, Graf C, et al. Five year survival, quality of life, and individual costs of 303 consecutive medical intensive care patients a cost utility analysis. Critical care medicine. Mar. 2005;33(3):547. Statistical Analysis. [pmid: 15753746].
337 Gray AM, Clarke P. The economic analyses of the UK prospective diabetes study. Diabetic Medicine. Aug. 2008;25(Suppl 2):47. Off topic. [pmid: 18717979].
338 Green C. Modelling disease progression in Alzheimer's disease: a review of modelling methods used for cost effectiveness analysis. PharmacoEconomics. 2007;25(9):735. Review. [pmid: 17803333].
339 Greenbaum S. Cost-benefit analysis of multifocal IOLs versus monovision pseudophakia. Journal of Cataract & Refractive Surgery. Apr. 2009;35(4):614. No abstract. [pmid: 19304070].
340 Greene BL, Miller JD, Brown TM, et al. Economic impact of the BP DownShift Program on blood pressure control among commercial driver license employees. Journal of Occupational & Environmental Medicine. May. 2009;51(5):542-53. Costs only. [pmid: 19365286].
341 GRESCA. Comparison of two management strategies for Helicobacter pylori treatment: clinical study and cost effectiveness analysis. Helicobacter. Feb. 2005;10(1):22. Statistical Analysis. [pmid: 15691312].
342 Griebsch I, Coast J, Brown J. Quality adjusted life years lack quality in pediatric care: a critical review of published cost utility studies in child health. Pediatrics. May. 2005;115(5):e600. Review. [pmid: 15867026].
343 Grieve R, Grishchenko M, Cairns J. SF-6D versus EQ-5D: reasons for differences in utility scores and impact on reported cost-utility. European Journal of Health Economics. Feb. 2009;10(1):15. Review. [pmid: 18327677].
344 Grieve R, Sekhon JS, Hu TW, et al. Evaluating health care programs by combining cost with quality of life measures: a case study comparing capitation and fee for service. Health services research. Aug. 2008;43(4):1204. Off topic. [pmid: 18355261].
345 Griffin S, Walker S, Sculpher M, et al. Cetuximab plus radiotherapy for the treatment of locally advanced squamous cell carcinoma of the head and neck. Health technology assessment (Winchester, England). Jun. 2009;13(Suppl 1):49. Review.
346 Grime KH, Bird J, Ferguson D, et al. Mechanism-based inhibition of cytochrome P450 enzymes: an evaluation of early decision making in vitro approaches and drug-drug interaction prediction methods. European Journal of Pharmaceutical Sciences. Feb. 15. 2009;36(2-3):175. Off topic. [pmid: 19013237].
347 Grobman WA. Decision analysis in obstetrics and gynecology. Obstetrical & gynecological survey. Sep. 2006;61(9):602. Off topic. [pmid: 16919178].
348 Groenen MJM, Ajodhia S, Wynstra JYF, et al. A cost-benefit analysis of endoscopy reporting methods: handwritten, dictated and computerized. Endoscopy. Jul. 2009;41(7):603-9. Costs only. [pmid: 19588288].
349 Groeneveld PW, Suh JJ, Matta MA. The costs and quality of life outcomes of drug eluting coronary stents: a systematic review. Journal of interventional cardiology. Feb. 2007;20(1):1. Review. [pmid: 17300390].
350 Grogan EL, Morris JA Jr., Dittus RS, et al. Cervical spine evaluation in urban trauma centers: lowering institutional costs and complications through helical CT scan. Journal of the American College of Surgeons. Feb. 2005;200(2):160. Cost Only. [pmid: 15664088].
351 Groot W, van den Brink HM. The value of health. BMC Health Services Research. 2008;8:136. Off topic. [pmid: 18578854].
352 Grootendorst P, Marshall D, Pericak D, et al. A model to estimate health utilities index mark 3 utility scores from WOMAC index scores in patients with osteoarthritis of the knee. Journal of Rheumatology. Mar. 2007;34(3):534. Off topic. [pmid: 17343301].
353 Grosse SD, Teutsch SM, Haddix AC. Lessons from cost effectiveness research for United States public health policy. Annual Review of Public Health. 2007;28:365. Off topic.
354 Grosse SD, Wordsworth S, Payne K. Economic methods for valuing the outcomes of genetic testing: beyond cost effectiveness analysis. Genetics in Medicine. Sep. 2008;10(9):648. Off topic. [pmid: 18978674].
355 Group S-BAP-MASDPMHJE. Cost utility of selective serotonin reuptake inhibitors for depression in primary care in Catalonia. Acta Psychiatrica Scandinavica. Supplementum. 2006;(432):39. Statistical Analysis. [pmid: 17087814].
356 Grover A, Gorman K, Dall TM, et al. Shortage of cardiothoracic surgeons is likely by 2020. Circulation. Aug. 11. 2009;120(6):488-94. Off topic. [pmid: 19635974].
357 Grutters JP, Joore MA, van der Horst F, et al. Choosing between measures: comparison of EQ 5D, HUI2 and HUI3 in persons with hearing complaints. Quality of Life Research. Oct. 2007;16(8):1439. Statistical Analysis. [pmid: 17647093].
358 Guerrero AM, Herrero C. A semi separable utility function for health profiles. Journal of health economics. Jan. 2005;24(1):33. Off topic. [pmid: 15617787].
359 Guilkey DK, Hutchinson P, Lance P. Cost effectiveness analysis for health communication programs. Journal of health communication. 2006;11(Suppl 2):47. Off topic. [pmid: 17148099].
360 Gunther OH, Roick C, Angermeyer MC, et al. Responsiveness of EQ 5D utility indices in alcohol dependent patients. Drug & Alcohol Dependence. Jan. 1. 2008;92(1 3):291. Off topic. [pmid: 17888587].
361 Gunther OH, Roick C, Angermeyer MC, et al. The responsiveness of EQ 5D utility scores in patients with depression: A comparison with instruments measuring quality of life, psychopathology and social functioning. Journal of affective disorders. Jan. 2008;105(1 3):81. Off topic. [pmid: 17532051].
362 Guo N, Marra CA, Marra F, et al. Health state utilities in latent and active tuberculosis. Value in Health. Dec. 2008;11(7):1154. Off topic. [pmid: 18489493].
363 Guo Y, Yao G, Lei B, et al. Monte Carlo model for studying the effects of melanin concentrations on retina light absorption. Journal of the Optical Society of America A, Optics, Image Science, & Vision. Feb. 2008;25(2):304. Off topic.
364 Gyrd-Hansen D. Willingness to pay for a QALY: theoretical and methodological issues. PharmacoEconomics. 2005;23(5):423. Off topic. [pmid: 15896094].
365 Gyrd-Hansen D, Kristiansen IS. Preferences for ‘life saving’ programmes: small for all or gambling for the prize?. Health economics. Jun. 2008;17(6):709. Off topic. [pmid: 17990283].
366 Haas DM, Imperiale TF, Kirkpatrick PR, et al. Tocolytic therapy: a meta-analysis and decision analysis. Obstetrics & Gynecology. Mar. 2009;113(3):585. Statistical Analysis. [pmid: 19300321].
367 Hackl W, Hoerbst A, Ammenwerth E. The electronic health record in Austria: physicians' acceptance is influenced by negative emotions. Studies in Health Technology & Informatics. 2009;150:140-4. Off topic. [pmid: 19745284].
368 Hahn RW, Kosec K, Neumann PJ, et al. What affects the quality of economic analysis for life saving investments?. Risk Analysis. Jun. 2006;26(3):641. Off topic. [pmid: 16834624].
369 Halpin DM. Health economics of chronic obstructive pulmonary disease. Proceedings of the American Thoracic Society. May. 2006;3(3):227. Off topic. [pmid: 16636090].
370 Hamidi V, Andersen MH, Oyen O, et al. Cost effectiveness of open versus laparoscopic living-donor nephrectomy. Transplantation. Mar. 27. 2009;87(6):831. Off topic. [pmid: 19300185].
371 Hamilton PW, van Diest PJ, Williams R, et al. Do we see what we think we see? The complexities of morphological assessment. Journal of Pathology. Jul. 2009;218(3):285. Off topic. [pmid: 19291709].
372 Hammerer PG, Kattan MW, Mottet N, et al. Using prostate specific antigen screening and nomograms to assess risk and predict outcomes in the management of prostate cancer. BJU international. Jul. 2006;98(1):11. Off topic. [pmid: 16566811].
373 Han D, Wang EC. Remission from depression : a review of venlafaxine clinical and economic evidence. PharmacoEconomics. 2005;23(6):567. Review. [pmid: 15960553].
374 Hanley B. An object simulation model for modeling hypothetical disease epidemics EpiFlex. Theoretical Biology & Medical Modelling. 2006;3:32. Off topic. [pmid: 16928271].
375 Hannawa AF. Negotiating medical virtues: toward the development of a physician mistake disclosure model. Health Communication. Jul. 2009;24(5):391-9. Off topic. [pmid: 19657822].
376 Hansen K, Lancon C, Toumi M. Pharmacoeconomic modelling in schizophrenia. Trap or support for decision makers?. European Journal of Health Economics. Mar. 2006;7(1):19. Review. [pmid: 16528579].
377 Hansen NR. Statistical models for local occurrences of RNA structures. Journal of Computational Biology. Jun. 2009;16(6):845-58. Off topic. [pmid: 19522667].
378 Hansen TB, Jacobsen F, Larsen K. Cost effective interprofessional training: an evaluation of a training unit in Denmark. Journal of Interprofessional Care. May. 2009;23(3):234. Off topic. [pmid: 19387912].
379 Hanson TE, Johnson WO, Gastwirth JL. Bayesian inference for prevalence and diagnostic test accuracy based on dual pooled screening. Biostatistics. Jan. 2006;7(1):41. Off topic. [pmid: 15947009].
380 Hansson E, Hansson T. The cost utility of lumbar disc herniation surgery. European Spine Journal. Mar. 2007;16(3):329. Statistical Analysis. [pmid: 16683121].
381 Harber P, Bansal S, Balmes J. Progression from beryllium exposure to chronic beryllium disease: an analytic model. Environmental Health Perspectives. Jun. 2009;117(6):970-4. Off topic. [pmid: 19590692].
382 Harbottle EJ, Birmingham CL, Sayani F. Anorexia nervosa: a survival analysis. Eating & Weight Disorders: EWD. Jun. 2008;13(2):e32. Off topic. [pmid: 18612251].
383 Hare WL, Alimadad A, Dodd H, et al. A deterministic model of home and community care client counts in British Columbia. Health Care Management Science. Mar. 2009;12(1):80-98. Off topic. [pmid: 19938444].
384 Harris AHS, Bowe T, Finney JW, et al. HEDIS initiation and engagement quality measures of substance use disorder care: impact of setting and health care specialty. Population Health Management. Aug. 2009;12(4):191-6. Off topic. [pmid: 19663621].
385 Harris C, Shannon R. An innovative enterostomal therapy nurse model of community wound care delivery: a retrospective cost effectiveness analysis. Journal of Wound, Ostomy, & Continence Nursing. discussion 184 5. Mar Apr. 2008;35(2):169. Statistical analysis.
386 Harrison MJ, Davies LM, Bansback NJ, et al. The validity and responsiveness of generic utility measures in rheumatoid arthritis: a review. Journal of Rheumatology. Apr. 2008;35(4):592. Review. [pmid: 18278841].
387 Hartnett E, Paoli GM, Schaffner DW. Modeling the public health system response to a terrorist event in the food supply. Risk Analysis. Nov. 2009;29(11):1506-20. Off topic. [pmid: 19732393].
388 Harvey S, Stevens K, Harrison D, et al. An evaluation of the clinical and cost effectiveness of pulmonary artery catheters in patient management in intensive care: a systematic review and a randomised controlled trial. Health technology assessment (Winchester, England). 1. 133. Aug. 2006;10(29):ix-xi. iii. Statistical Analysis.
389 Hasegawa T, Yoshida E, Kobayashi A, et al. Evaluation of static physics performance of the jPET D4 by Monte Carlo simulations. Physics in Medicine & Biology. Jan. 7. 2007;52(1):213. Off topic. [pmid: 17183137].
390 Haspel J, Bauer K, Goehler A, et al. Long-term anticoagulant therapy for idiopathic pulmonary embolism in the elderly: a decision analysis. Chest. May. 2009;135(5):1243. [pmid: 19017863].
391 Hass B, Lungershausen J, Hertel N, et al. Cost-effectiveness of strong opioids focussing on the long-term effects of opioid-related fractures: a model approach. European Journal of Health Economics. Jul. 2009;10(3):309. [pmid: 19101743].
392 Hassan C, Hunink MGM, Laghi A, et al. Value-of-information analysis to guide future research in colorectal cancer screening. Radiology. Dec. 2009;253(3):745-52. Review. [pmid: 19789242].
393 Hatoum HT, Walton SM. Discussion of “Comparison of clinical and cost effectiveness of 3 intervention strategies for HIV wasting”. Journal of Acquired Immune Deficiency Syndromes: JAIDS. author reply 237-8. Oct. 1. 2005;40(2):236. Cost only.
394 Hatten AL, Gatchel RJ, Polatin PB, et al. A cost utility analysis of chronic spinal pain treatment outcomes: converting SF 36 data into quality adjusted life years. Clinical Journal of Pain. Oct. 2006;22(8):700. Statistical Analysis. [pmid: 16988566].
395 Hawkes M, Katsuva JP, Masumbuko CK. Use and limitations of malaria rapid diagnostic testing by community health workers in war-torn Democratic Republic of Congo. Malaria Journal. 2009;8(1):308. Off topic. [pmid: 20028563].
396 Hawkins N, Sculpher M, Epstein D. Cost effectiveness analysis of treatments for chronic disease: using R to incorporate time dependency of treatment response. Medical Decision Making. Sep-Oct. 2005;25(5):511. Off topic. [pmid: 16160207].
397 Hayes E, Moroz L, Pizzi L, et al. A cost decision analysis of 4 tocolytic drugs. American Journal of Obstetrics & Gynecology. Oct. 2007;197(4):383.e1. Cost Only. [pmid: 17904969].
398 Heidinger JC, Winter CK, Cullor JS. Quantitative microbial risk assessment for Staphylococcus aureus and Staphylococcus enterotoxin A in raw milk. Journal of Food Protection. Aug. 2009;72(8):1641-53. Off topic. [pmid: 19722395].
399 Hejblum G, Atsou K, Dautzenberg B, et al. Cost-benefit analysis of a simulated institution-based preoperative smoking cessation intervention in patients undergoing total hip and knee arthroplasties in France. Chest. Feb. 2009;135(2):477-83. Costs only. [pmid: 18719060].
400 Hektoen LF, Aas E, Luras H. Cost-effectiveness in fall prevention for older women. Scandinavian journal of public health. Aug. 2009;37(6):584. Cost Only. [pmid: 19666674].
401 Helle-Valle T, Remme EW, Lyseggen E, et al. Clinical assessment of left ventricular rotation and strain: a novel approach for quantification of function in infarcted myocardium and its border zones. American Journal of Physiology Heart & Circulatory Physiology. Jul. 2009;297(1):H257-67. Off topic. [pmid: 19395547].
402 Hengge UR, Wallerand A, Stutzki A, et al. Cost effectiveness of reduced follow up in malignant melanoma. Journal der Deutschen Dermatologischen Gesellschaft. Oct. 2007;5(10):898. Statistical Analysis. [pmid: 17910672].
403 Herman PM, Avery DJ, Schemp CS, et al. Are cost-inclusive evaluations worth the effort?. Evaluation & Program Planning. Feb. 2009;32(1):55-61. Off topic. [pmid: 18977533].
404 Herman PM, Szczurko O, Cooley K, et al. Cost effectiveness of naturopathic care for chronic low back pain. Alternative Therapies in Health & Medicine. Mar Apr. 2008;14(2):32. Off topic. [pmid: 18383988].
405 Hernandez RA, de Verteuil RM, Fraser CM, et al. Systematic review of economic evaluations of laparoscopic surgery for colorectal cancer. Colorectal Disease. Nov. 2008;10(9):859. Review. [pmid: 18624821].
406 Herrera A, Panisello JJ, Ibarz E, et al. Comparison between DEXA and finite element studies in the long-term bone remodeling of an anatomical femoral stem. Journal of Biomechanical Engineering. Apr. 2009;131(4):041013. Off topic. [pmid: 19275442].
407 Hiley MJ, Wangler R, Predescu G. Optimization of the felge on parallel bars. Sports Biomechanics. Mar. 2009;8(1):39-51. Off topic. [pmid: 19391493].
408 Hiligsmann M, Ethgen O, Richy F, et al. Utility values associated with osteoporotic fracture: a systematic review of the literature. Calcified tissue international. Apr. 2008;82(4):288. Review. [pmid: 18404243].
409 Hill RA, Boland A, Dickson R, et al. Drug eluting stents: a systematic review and economic evaluation. Health technology assessment (Winchester, England). Nov. 2007;11(46):xi-221. iii. xi. Review.
410 Hillner BE, Smith TJ. Efficacy does not necessarily translate to cost effectiveness: a case study in the challenges associated with 21st-century cancer drug pricing. Journal of Clinical Oncology. May. 1. 2009;27(13):2111. Review. [pmid: 19332715].
411 Hislop SJ, Hedrick JH, Singh MJ, et al. Simulation case rehearsals for carotid artery stenting. European Journal of Vascular & Endovascular Surgery. Dec. 2009;38(6):750-4. Off topic. [pmid: 19801196].
412 Hlatky MA, Owens DK, Sanders GD. Cost effectiveness as an outcome in randomized clinical trials. Clinical Trials. 2006;3(6):543. Off topic. [pmid: 17170039].
413 Hoch JS, Dewa CS. Lessons from trial based cost effectiveness analyses of mental health interventions: why uncertainty about the outcome, estimate and willingness to pay matters. PharmacoEconomics. 2007;25(10):807. Off topic. [pmid: 17887803].
414 Hoch JS, Dewa CS. A clinician's guide to correct cost effectiveness analysis: think incremental not average. Canadian Journal of Psychiatry Revue Canadienne de Psychiatrie. Apr. 2008;53(4):267. Off topic. [pmid: 18478830].
415 Hoch JS, Rockx MA, Krahn AD. Using the net benefit regression framework to construct cost effectiveness acceptability curves: an example using data from a trial of external loop recorders versus Holter monitoring for ambulatory monitoring of “community acquired” syncope. BMC Health Services Research. 2006;6:68. Statistical Analysis. [pmid: 16756680].
416 Hoch JS, Smith MW. A guide to economic evaluation: methods for cost effectiveness analysis of person level data. Journal of traumatic stress. Dec. 2006;19(6):787. Off topic. [pmid: 17195977].
417 Hoerger TJ. Using costs in cost-effectiveness models for chronic diseases: lessons from diabetes. Medical care. Jul. 2009;47(7 Suppl 1):S21. Review. [pmid: 19536014].
418 Hollenbeak CS, Lendel I, Beus KS, et al. The cost of screening for synchronous thyroid disease in patients presenting with primary hyperparathyroidism. Archives of Otolaryngology Head & Neck Surgery. Oct. 2007;133(10):1013. Cost Only. [pmid: 17938325].
419 Holmes J, Hemmett L, Garfield S. The cost effectiveness of human papillomavirus screening for cervical cancer. A review of recent modelling studies. European Journal of Health Economics. Mar. 2005;6(1):30. Review. [pmid: 15682286].
420 Holtgrave DR, Wunderink KA, Vallone DM, et al. Cost-utility analysis of the National truth campaign to prevent youth smoking. American Journal of Preventive Medicine. May. 2009;36(5):385. Cost Only. [pmid: 19211214].
421 Home PD. Cost effectiveness of CSII. Diabetic Medicine. author reply 707-8. Jun. 2006;23(6):707. Cost only. [pmid: 16759317].
422 Hong YM, Loughlin KR. Economic impact of tumor markers in bladder cancer surveillance. Urology. Jan. 2008;71(1):131. Review. [pmid: 18242381].
423 Hoomans T, Severens JL, Evers SM, et al. Value for money in changing clinical practice: should decisions about guidelines and implementation strategies be made sequentially or simultaneously?. Medical Decision Making. Mar-Apr. 2009;29(2):207. Off topic. [pmid: 19237645].
424 Hoomans T, Severens JL, Evers SMAA, et al. Value for money in changing clinical practice: should decisions about guidelines and implementation strategies be made sequentially or simultaneously?. Medical Decision Making. Mar-Apr. 2009;29(2):207-16. Off topic. [pmid: 19237645].
425 Hormozdiari F, Salari R, Hsing M, et al. The effect of insertions and deletions on wirings in protein-protein interaction networks: a large-scale study. Journal of Computational Biology. Feb. 2009;16(2):159-67. Off topic. [pmid: 19193143].
426 Hornberger J, Holodniy M, Robertus K, et al. A systematic review of cost utility analyses in HIV/AIDS: implications for public policy. Medical Decision Making. Nov Dec. 2007;27(6):789. Review. [pmid: 18057191].
427 Hosking FJ, Sterne JA, Smith GD, et al. Inference from genome wide association studies using a novel Markov model. Genetic epidemiology. Sep. 2008;32(6):497. Off topic. [pmid: 18383184].
428 Hoskins HD Jr. Glaucoma care cost-effectiveness. Ophthalmology. May. 2009;116(5):1016. Review. [pmid: 19410965].
429 Hsieh CR, Sloan FA. Adoption of pharmaceutical innovation and the growth of drug expenditure in Taiwan: is it cost effective?. Value in Health. Mar Apr. 2008;11(2):334. Statistical analysis. [pmid: 18380646].
430 Hsieh MH, Meng MV. Decision analysis and Markov modeling in urology. Journal of Urology. Nov. 2007;178(5):1867. Off topic. [pmid: 17868735].
431 Hsieh MH, Roth DR, Meng MV. Economic analysis of infant vs postpubertal orchiopexy to prevent testicular cancer. Urology. Apr. 2009;73(4):776. Cost Only. [pmid: 19193413].
432 Hu D, Hook EW 3rd, Goldie SJ. The impact of natural history parameters on the cost effectiveness of Chlamydia trachomatis screening strategies. Sexually transmitted diseases. Jul. 2006;33(7):428. Review. [pmid: 16572038].
433 Huang ES, Basu A, O'Grady M, et al. Projecting the future diabetes population size and related costs for the U.S. Diabetes Care. Dec. 2009;32(12):2225-9. Off topic. [pmid: 19940225].
434 Huang Y, Zhang R, Culler SD, et al. Costs and effectiveness of cardiac rehabilitation for dialysis patients following coronary bypass. Kidney international. Oct. 2008;74(8):1079. Statistical analysis. [pmid: 18650790].
435 Huda S, Yearwood J, Togneri R. A constraint-based evolutionary learning approach to the expectation maximization for optimal estimation of the hidden Markov model for speech signal modeling. IEEE Transactions on Systems, Man, & Cybernetics, Part B: Cybernetics. Feb. 2009;39(1):182-97. Off topic.
436 Hughes D, Cowell W, Koncz T, et al. Methods for integrating medication compliance and persistence in pharmacoeconomic evaluations. Value in Health. Nov Dec. 2007;10(6):498. Review. [pmid: 17970932].
437 Hughes DA, Bayoumi AM, Pirmohamed M. Current assessment of risk benefit by regulators: is it time to introduce decision analyses?. Clinical Pharmacology & Therapeutics. Aug. 2007;82(2):123. Off topic. [pmid: 17632534].
438 Hughes J. Palliative care and the QALY problem. Health Care Analysis. Dec. 2005;13(4):289. Off topic. [pmid: 16435466].
439 Hughes S, Cuffe RL, Lieftucht A, et al. Informing the selection of futility stopping thresholds: case study from a late-phase clinical trial. Pharmaceutical Statistics. Jan-Mar. 2009;8(1):25. Review. [pmid: 18383194].
440 Hui-Min Wu G, Chang SH, Hsiu-Hsi Chen T. A bayesian random effects markov model for tumor progression in women with a family history of breast cancer. Biometrics. Dec. 2008;64(4):1231. Off topic. [pmid: 18218063].
441 Hummel JM, Snoek GJ, van Til JA, et al. A multicriteria decision analysis of augmentative treatment of upper limbs in persons with tetraplegia. Journal of Rehabilitation Research & Development. Sep-Oct. 2005;42(5):635. Statistical Analysis. [pmid: 16586189].
442 Hung GR, Kissoon N. Impact of an observation unit and an emergency department-admitted patient transfer mandate in decreasing overcrowding in a pediatric emergency department: a discrete event simulation exercise. Pediatric Emergency Care. Mar. 2009;25(3):160-3. Off topic. [pmid: 19262424].
443 Hurwitz SJ, Asif G, Schinazi RF. Development of a population simulation model for HIV monotherapy virological outcomes using lamivudine. Antiviral Chemistry & Chemotherapy. 2007;18(6):329. Off topic. [pmid: 18320937].
444 Hutchinson J, Scott DA, Clegg AJ, et al. Cost effectiveness of left ventricular assist devices in end stage heart failure. Expert Review of Cardiovascular Therapy. Feb. 2008;6(2):175. Review. [pmid: 18248272].
445 Hutchinson P, Wheeler J. The cost effectiveness of health communication programs: what do we know?. Journal of health communication. 2006;11(Suppl 2):7. Review. [pmid: 17148098].
446 Hutton G, Schellenberg D, Tediosi F, et al. Cost-effectiveness of malaria intermittent preventive treatment in infants (IPTi) in Mozambique and the United Republic of Tanzania. Bulletin of the World Health Organization. Feb. 2009;87(2):123. Off topic. [pmid: 19274364].
447 Hutubessy RC, Niessen LW, Dijkstra RF, et al. Stochastic league tables: an application to diabetes interventions in the Netherlands. Health economics. May. 2005;14(5):445. Off topic. [pmid: 15386648].
448 Icks A, Rathmann W, Haastert B, et al. Cost effectiveness of type 2 diabetes screening: results from recently published studies. Gesundheitswesen. Aug. 2005;67(Suppl 1):S167. Review. [pmid: 16032536].
449 Ikeda S, Kobayashi M, Fukuhara S, et al. Cost effectiveness of Liple (LipoPGE1) for arteriosclerosis obliterans patients in Japan: an economic evaluation using the EQ 5D instrument. International Angiology. Jun. 2006;25(2):169. Statistical Analysis. [pmid: 16763534].
450 Imai H, Kuroi K, Ohsumi S, et al. Economic evaluation of the prevention and treatment of breast cancer present status and open issues. Breast Cancer. 2007;14(1):81. Review. [pmid: 17245000].
451 Imamura T, Yasunaga H. Economic evaluation of prostate cancer screening with prostate specific antigen. International Journal of Urology. Apr. 2008;15(4):285. Review. [pmid: 18380812].
452 Imbo I, LeFevre JA. Cultural differences in complex addition: efficient Chinese versus adaptive Belgians and Canadians. Journal of Experimental Psychology: Learning, Memory, & Cognition. Nov. 2009;35(6):1465-76. Off topic.
453 Insinga RP, Glass AG, Myers ER, et al. Abnormal outcomes following cervical cancer screening: event duration and health utility loss. Medical Decision Making. Jul Aug. 2007;27(4):414. Statistical Analysis. [pmid: 17585005].
454 Isaacman DJ, Strutton DR, Kalpas EA, et al. The impact of indirect (herd) protection on the cost effectiveness of pneumococcal conjugate vaccine. Clinical therapeutics. Feb. 2008;30(2):341. Review. [pmid: 18343273].
455 Ise Y, Hagiwara K, Onda M, et al. Pharmaceutical cost comparison analysis of antimicrobial use for surgical prophylaxis on gastrectomy patients in a tertiary care hospital. Chemotherapy. Oct. 2005;51(6):384. Cost Only. [pmid: 16227697].
456 Ishida K, Imai H, Ogasawara K, et al. Cost utility of living donor liver transplantation in a single Japanese center. Hepato gastroenterology. Jul-Aug. 2006;53(70):588. Statistical Analysis. [pmid: 16995468].
457 Itan Y, Powell A, Beaumont MA, et al. The origins of lactase persistence in Europe. PLoS Computational Biology. Aug. 2009;5(8):e1000491. Off topic. [pmid: 19714206].
458 Itoh H, Sakaguchi T, Ding WG, et al. Latent genetic backgrounds and molecular pathogenesis in drug-induced long-QT syndrome. Circulation: Arrhythmia and Electrophysiology. Oct. 2009;2(5):511-23. Off topic. [pmid: 19843919].
459 Jackson BR, Thomas A, Carroll KC, et al. Use of strain typing data to estimate bacterial transmission rates in healthcare settings. Infection Control & Hospital Epidemiology. Jul. 2005;26(7):638. Off topic. [pmid: 16092745].
460 Jacobsson F, Carstensen J, Borgquist L. Caring externalities in health economic evaluation: how are they related to severity of illness?. Health Policy. Aug. 2005;73(2):172. Off topic. [pmid: 15978960].
461 Jacquemyn Y, Van Overmeire B. Tocolytic therapy: a meta-analysis and decision analysis. Obstetrics & Gynecology. author reply 171. Jul. 2009;114(1):170. Review. [pmid: 19546783].
462 Jagger C, Matthews R, Lindesay J, et al. The effect of dementia trends and treatments on longevity and disability: a simulation model based on the MRC Cognitive Function and Ageing Study (MRC CFAS). Age & Ageing. May. 2009;38(3):319-25. discussion 251. Off topic. [pmid: 19258397].
463 Jefferis K, Kinghorn A, Siphambe H, et al. Macroeconomic and household level impacts of HIV/AIDS in Botswana. Aids. Jul. 2008;22(Suppl 1):S113. Costs only. [pmid: 18664942].
464 Jehu-Appiah C, Baltussen R, Acquah C, et al. Balancing equity and efficiency in health priorities in Ghana: the use of multicriteria decision analysis. Value in Health. Dec. 2008;11(7):1081. Off topic. [pmid: 19602214].
465 Jena AB, Philipson TJ. Cost effectiveness analysis and innovation. Journal of health economics. Sep. 2008;27(5):1224. Off topic. [pmid: 18619695].
466 Johansson M, Pipkorn B, Lovsund P. Child safety in vehicles: validation of a mathematical model and development of restraint system design guidelines for 3-year-olds through mathematical simulations. Traffic Injury Prevention. Oct. 2009;10(5):467-78. Off topic. [pmid: 19746311].
467 Johnson FR, Backhouse M. Eliciting stated preferences for health technology adoption criteria using paired comparisons and recommendation judgments. Value in Health. Sep-Oct. 2006;9(5):303. Off topic. [pmid: 16961548].
468 Johri M, Damschroder LJ, Zikmund-Fisher BJ, et al. The importance of age in allocating health care resources: does intervention type matter?. Health economics. Jul. 2005;14(7):669. Off topic. [pmid: 15497189].
469 Joish VN, Oderda GM. Cost utility analysis and quality adjusted life years. Journal of Pain & Palliative Care Pharmacotherapy. 2005;19(1):57. Off topic. [pmid: 15814516].
470 Jones RM, Masago Y, Bartrand T, et al. Characterizing the risk of infection from Mycobacterium tuberculosis in commercial passenger aircraft using quantitative microbial risk assessment. Risk Analysis. Mar. 2009;29(3):355. Statistical Analysis. [pmid: 19076326].
471 Jonsson B, Carides GW, Burke TA, et al. Cost effectiveness of losartan in patients with hypertension and LVH: an economic evaluation for Sweden of the LIFE trial. Journal of hypertension. Jul. 2005;23(7):1425. Statistical Analysis. [pmid: 15942467].
472 Joubert J, Norman R, Bradshaw D, et al. Estimating the burden of disease attributable to excess body weight in South Africa in 2000. South African Medical Journal.Suid Afrikaanse Tydskrif Vir Geneeskunde. Aug. 2007;97(8 Pt 2):683. Off topic. [pmid: 17952225].
473 Joubert J, Norman R, Lambert EV, et al. Estimating the burden of disease attributable to physical inactivity in South Africa in 2000. South African Medical Journal.Suid Afrikaanse Tydskrif Vir Geneeskunde. Aug. 2007;97(8 Pt 2):725. Off topic. [pmid: 17952230].
474 Kadri S, Hinman V, Benos PV. HHMMiR: efficient de novo prediction of microRNAs using hierarchical hidden Markov models. BMC Bioinformatics. Suppl 1. 2009;10:S35. Off topic. [pmid: 19208136].
475 Kahaleh M, Brock A, Conaway MR, et al. Covered self expandable metal stents in pancreatic malignancy regardless of resectability: a new concept validated by a decision analysis. Endoscopy. Apr. 2007;39(4):319. Statistical Analysis. [pmid: 17357951].
476 Kamal KM, Miller LA, Kavookjian J, et al. Alternative decision analysis modeling in the economic evaluation of tumor necrosis factor inhibitors for rheumatoid arthritis. Seminars in Arthritis & Rheumatism. Aug. 2006;36(1):50. Review. [pmid: 16887468].
477 Kaplan RM. The future of outcomes measurement in rheumatology. American Journal of Managed Care. Dec. 2007;13(Suppl 9):S252. Off topic. [pmid: 18095788].
478 Kaplan RM, Groessl EJ, Sengupta N, et al. Comparison of measured utility scores and imputed scores from the SF 36 in patients with rheumatoid arthritis. Medical care. Jan. 2005;43(1):79. Off topic. [pmid: 15626937].
479 Kapur VK, Alfonso-Cristancho R. Just a good deal or truly a steal? Medical cost savings and the impact on the cost-effectiveness of treating sleep apnea. Sleep. Feb. 1. 2009;32(2):135. Review. [pmid: 19238798].
480 Karanicolas PJ, Smith SE, Inculet RI, et al. The cost of laparoscopic myotomy versus pneumatic dilatation for esophageal achalasia. Surgical endoscopy. Jul. 2007;21(7):1198. Cost Only. [pmid: 17479318].
481 Karlovsek MZ, Balazic J. Evaluation of the post rotational nystagmus test (PRN) in determining alcohol intoxication. Journal of analytical toxicology. Jul-Aug. 2005;29(5):390. Off topic. [pmid: 16105267].
482 Karlsson S, Ruokonen E, Varpula T, et al. Long-term outcome and quality-adjusted life years after severe sepsis. Critical care medicine. Apr. 2009;37(4):1268. Off topic. [pmid: 19242321].
483 Karnon J, Campbell F, Czoski-Murray C. Model-based cost-effectiveness analysis of interventions aimed at preventing medication error at hospital admission (medicines reconciliation). Journal of evaluation in clinical practice. Apr. 2009;15(2):299. Off topic. [pmid: 19335488].
484 Karnon J, Carlton J, Czoski-Murray C, et al. Informing disinvestment through cost-effectiveness modelling: is lack of data a surmountable barrier?. Applied Health Economics & Health Policy. 2009;7(1):1. Off topic. [pmid: 19558190].
485 Karp NA, Lilley KS. Investigating sample pooling strategies for DIGE experiments to address biological variability. Proteomics. Jan. 2009;9(2):388-97. Off topic. [pmid: 19105178].
486 Kastanioti CK, Kolettis TM, Stavridis G, et al. Cost effectiveness of on pump and off pump bypass surgery. European heart journal. May. 2005;26(10):1046. Cost only. [pmid: 15821002].
487 Kazembe LN, Muula AS, Appleton CC, et al. Modelling the effect of malaria endemicity on spatial variations in childhood fever, diarrhoea and pneumonia in Malawi. International Journal of Health Geographics [Electronic Resource]. 2007;6:33. Statistical Analysis.
488 Kazembe LN, Namangale JJ. A Bayesian multinomial model to analyse spatial patterns of childhood co morbidity in Malawi. European journal of epidemiology. 2007;22(8):545. Off topic. [pmid: 17565446].
489 Keating CL, Dixon JB, Moodie ML, et al. Cost-effectiveness of surgically induced weight loss for the management of type 2 diabetes: modeled lifetime analysis. Diabetes care. Apr. 2009;32(4):567. [pmid: 19171720].
490 Kellett J. Prognostication the lost skill of medicine. European journal of internal medicine. May. 2008;19(3):155. Off topic. [pmid: 18395158].
491 Kennedy AS, Kleinstreuer C, Basciano CA, et al. Computer modeling of yttrium-90-microsphere transport in the hepatic arterial tree to improve clinical outcomes. International Journal of Radiation Oncology, Biology, Physics. Feb. 1. 2010;76(2):631-7. Off topic.
492 Kenron DA, Jimenez-Santana P, Casper GR. Use of a matrix to select home based technology for HeartCare II. AMIA . Annual Symposium Proceedings/AMIA Symposium. 2005:1006. Off topic.
493 Kerrigan CL, Stanwix MG. Using evidence to minimize the cost of trigger finger care. Journal of Hand Surgery American Volume. Jul-Aug. 2009;34(6):997-1005. Costs only.
494 Khankari K, Eder M, Osborn CY, et al. Improving colorectal cancer screening among the medically underserved: a pilot study within a federally qualified health center. Journal of General Internal Medicine. Oct. 2007;22(10):1410. Statistical Analysis. [pmid: 17653808].
495 Khanna D, Ahmed M, Furst DE, et al. Health values of patients with systemic sclerosis. Arthritis & Rheumatism. Feb. 15. 2007;57(1):86. Off topic. [pmid: 17266070].
496 Khare RK, Powell ES, Reinhardt G, et al. Adding more beds to the emergency department or reducing admitted patient boarding times: which has a more significant influence on emergency department congestion?. Annals of Emergency Medicine. May. 2009;53(5):575. Off topic. [pmid: 18783852].
497 Khaykin Y, Wang X, Natale A, et al. Cost comparison of ablation versus antiarrhythmic drugs as first-line therapy for atrial fibrillation: an economic evaluation of the RAAFT pilot study. Journal of cardiovascular electrophysiology. Jan. 2009;20(1):7. Cost Only. [pmid: 18803564].
498 Kikuchi T, Gittins J. A behavioral Bayes method to determine the sample size of a clinical trial considering efficacy and safety. Statistics in medicine. Aug. 15. 2009;28(18):2293. Off topic. [pmid: 19536745].
499 Kim JJ, Brisson M, Edmunds WJ, et al. Modeling cervical cancer prevention in developed countries. Vaccine. Aug. 19. 2008;26(Suppl 10):K76. Review. [pmid: 18847560].
500 Kim JJ, Salomon JA, Weinstein MC, et al. Packaging health services when resources are limited: the example of a cervical cancer screening visit. PLoS Medicine / Public Library of Science. Nov. 2006;3(11):e434. Off topic.
501 Kim WR. The use of decision analytic models to inform clinical decision making in the management of hepatocellular carcinoma. Clinics in liver disease. May. 2005;9(2):225. Off topic. [pmid: 15831270].
502 King JT Jr., Tsevat J, Lave JR, et al. Willingness to pay for a quality adjusted life year: implications for societal health care resource allocation. Medical Decision Making. Nov-Dec. 2005;25(6):667. Off topic. [pmid: 16282217].
503 King JT Jr., Tsevat J, Roberts MS. Preference based quality of life in patients with cerebral aneurysms. Stroke. Feb. 2005;36(2):303. Off topic. [pmid: 15653579].
504 King RC, Atallah L, Lo BPL, et al. Development of a wireless sensor glove for surgical skills assessment. IEEE Transactions on Information Technology in Biomedicine. Sep. 2009;13(5):673-9. Off topic. [pmid: 19726263].
505 Kirby J, Green C, Loveman E, et al. A systematic review of the clinical and cost effectiveness of memantine in patients with moderately severe to severe Alzheimer's disease. Drugs & aging. 2006;23(3):227. Review. [pmid: 16608378].
506 Kjellberg AT, Carlsson P, Bergh C. Randomized single versus double embryo transfer: obstetric and paediatric outcome and a cost effectiveness analysis. Human Reproduction. Jan. 2006;21(1):210. Statistical Analysis. [pmid: 16172148].
507 Klok RM, Arents NL, de Vries R, et al. Economic evaluation of a randomized trial comparing Helicobacter pylori test and treat and prompt endoscopy strategies for managing dyspepsia in a primary care setting. Clinical therapeutics. Oct. 2005;27(10):1647. Statistical Analysis. [pmid: 16330302].
508 Knoester PD, Boendermaker AJ, Egberts AC, et al. Cost effectiveness of add on lamotrigine therapy in clinical practice. Epilepsy research. Dec. 2005;67(3):143. Off topic. [pmid: 16288850].
509 Kobelt G, Lindgren P, Lindroth Y, et al. Modelling the effect of function and disease activity on costs and quality of life in rheumatoid arthritis. Rheumatology. Sep. 2005;44(9):1169. Off topic. [pmid: 15956093].
510 Kolker A. Process modeling of ICU patient flow: effect of daily load leveling of elective surgeries on ICU diversion. Journal of Medical Systems. Feb. 2009;33(1):27-40. Off topic. [pmid: 19238894].
511 Kolker JL, Damiano PC, Flach SD, et al. The cost effectiveness of large amalgam and crown restorations over a 10 year period. Journal of public health dentistry. 2006;66(1):57. Off topic. [pmid: 16570752].
512 Koltowska-Haggstrom M, Jonsson B, Isacson D, et al. Using EQ 5D to derive general population based utilities for the quality of life assessment of growth hormone deficiency in adults (QoL AGHDA). Value in Health. Jan Feb. 2007;10(1):73. Off topic. [pmid: 17261118].
513 Kong CY, McMahon PM, Gazelle GS. Calibration of disease simulation model using an engineering approach. Value in Health. Jun. 2009;12(4):521-9. Statistical analysis. [pmid: 19900254].
514 Koopmans CM, van Pampus MG, Groen H, et al. Accuracy of serum uric acid as a predictive test for maternal complications in pre-eclampsia: bivariate meta-analysis and decision analysis. European Journal of Obstetrics, Gynecology, & Reproductive Biology. Sep. 2009;146(1):8-14. Statistical analysis.
515 Korenkov M, Sauerland S, Junginger T. Surgery for obesity. Current opinion in gastroenterology. Nov. 2005;21(6):679. Off topic. [pmid: 16220044].
516 Krein SL, Funnell MM, Piette JD. Economics of diabetes mellitus. Nursing Clinics of North America. Dec. 2006;41(4):v-vi. 499. Off topic.
517 Krol M, Brouwer W, Sendi P. Productivity costs in health state valuations : does explicit instruction matter?. PharmacoEconomics. 2006;24(4):401. Off topic. [pmid: 16605285].
518 Krol M, Koopman M, Uyl-de Groot C, et al. A systematic review of economic analyses of pharmaceutical therapies for advanced colorectal cancer. Expert opinion on pharmacotherapy. Jun. 2007;8(9):1313. Review. [pmid: 17563265].
519 Krumme B. Comparing the cost effectiveness of various approaches to the management of suspected renal artery stenosis. Nature Clinical Practice Nephrology. Feb. 2008;4(2):70. No abstract.
520 Krummenauer F, Gunther KP, Witzlebf WC. The incremental cost effectiveness of in patient versus out patient rehabilitation after total hip arthroplasty results of a pilot investigation. European journal of medical research. Jun. 24. 2008;13(6):267. Off topic. [pmid: 18558552].
521 Krummenauer F, Landwehr I. Incremental cost effectiveness evaluation in clinical research. European journal of medical research. Jan. 28. 2005;10(1):18. Off topic. [pmid: 15737949].
522 Kumar S, Swanson E, Tran T. RFID in the healthcare supply chain: usage and application. International Journal of Health Care Quality Assurance. 2009;22(1):67-81. Off topic. [pmid: 19284172].
523 Kurt M, Shaikh KA, Peterson L, et al. Impact of contrast echocardiography on evaluation of ventricular function and clinical management in a large prospective cohort. Journal of the American College of Cardiology. Mar. 3. 2009;53(9):802-10. Off topic. [pmid: 19245974].
524 Kymes S. Clinical outcomes of glaucoma treatment over a patient lifetime: a Markov model (letter). Journal of glaucoma. author reply 472-3. Oct. 2006;15(5):471. Cost only. [pmid: 16988613].
525 Kymes SM. An introduction to decision analysis in the economic evaluation of the prevention and treatment of vision related diseases. Ophthalmic epidemiology. Mar Apr. 2008;15(2):76. Off topic. [pmid: 18432490].
526 Kymes SM, Lee BS. Preference based quality of life measures in people with visual impairment. Optometry & Vision Science. Aug. 2007;84(8):809. Off topic. [pmid: 17700344].
527 Ladapo JA, Neumann PJ, Keren R, et al. Valuing children's health: a comparison of cost utility analyses for adult and paediatric health interventions in the US. PharmacoEconomics. 2007;25(10):817. Review. [pmid: 17887804].
528 Lahausse JA, Fildes BN. Cost-benefit analysis of an alcohol ignition interlock for installation in all newly registered vehicles. Traffic Injury Prevention. Dec. 2009;10(6):528-37. Off topic. [pmid: 19916122].
529 Laking G, Lord J, Fischer A. The economics of diagnosis. Health economics. Oct. 2006;15(10):1109. Off topic. [pmid: 16652389].
530 Lamers LM, Uyl-de Groot CA, Buijt I. The use of disease specific outcome measures in cost utility analysis: the development of Dutch societal preference weights for the FACT L scale. PharmacoEconomics. 2007;25(7):591. Off topic. [pmid: 17610339].
531 Lamparter J, Dick HB, Krummenauer F. Clinical benefit, complication patterns and cost effectiveness of laser in situ keratomileusis (LASIK) in moderate myopia: results of independent meta analyses on clinical outcome and postoperative complication profiles. European journal of medical research. Sep. 12. 2005;10(9):402. Off topic. [pmid: 16183554].
532 Lansingh VC, Carter MJ. Use of Global Visual Acuity Data in a time trade-off approach to calculate the cost utility of cataract surgery. Archives of Ophthalmology. Sep. 2009;127(9):1183. [pmid: 19752429].
533 Laohavaleeson S, Barriere SL, Nicolau DP, et al. Cost effectiveness of telavancin versus vancomycin for treatment of complicated skin and skin structure infections. Pharmacotherapy. Dec. 2008;28(12):1471. Statistical analysis. [pmid: 19025428].
534 Lara AM, Wakholi BN, Kasirye A, et al. Utility assessment of HIV/AIDS related health states in HIV infected Ugandans. Aids. Jul. 2008;22(Suppl 1):S123. Off topic. [pmid: 18664944].
535 Lau A, Gregor JC. Resource implications for a population based colorectal cancer screening program in Canada: a study of the impact on colonoscopy capacity and costs in London, Ontario. Canadian Journal of Gastroenterology. Jun. 2007;21(6):371. Cost Only. [pmid: 17571171].
536 Laufer F. Thresholds in cost effectiveness analysis more of the story. Value in Health. Jan-Feb. 2005;8(1):86. Cost only. [pmid: 15841899].
537 Laufer S, Rubinsky B. Tissue characterization with an electrical spectroscopy SVM classifier. IEEE Transactions on Biomedical Engineering. Feb. 2009;56(2):525-8. Off topic. [pmid: 19342332].
538 Lawrentschuk N, Fleshner N. The role of magnetic resonance imaging in targeting prostate cancer in patients with previous negative biopsies and elevated prostate-specific antigen levels. BJU International. Mar. 2009;103(6):730-3. Statistical analysis. [pmid: 19154475].
539 Leal J, Wordsworth S, Legood R, et al. Eliciting expert opinion for economic models: an applied example. Value in Health. May Jun. 2007;10(3):195. Off topic. [pmid: 17532812].
540 Leaphart CL, Borland K, Kane TD, et al. Hypertrophic pyloric stenosis in newborns younger than 21 days: remodeling the path of surgical intervention. Journal of pediatric surgery. Jun. 2008;43(6):998. Off topic. [pmid: 18558172].
541 Lebcir RM, Choudrie J, Atun RA, et al. Using a decision support systems computer simulation model to examine HIV and tuberculosis: the Russian Federation. International Journal of Electronic Healthcare. 2009;5(1):14-32. Review. [pmid: 19505866].
542 Leclerc PM, Matthews AP, Garenne ML. Fitting the HIV epidemic in Zambia: a two-sex micro-simulation model. PLoS ONE [Electronic Resource]. 2009;4(5):e5439. Off topic.
543 Lee A, Joynt GM, Ho AM, et al. Effect of an integrated teaching intervention on clinical decision analysis: a randomized, controlled study of undergraduate medical students. Medical teacher. Mar. 2007;29(2 3):231. Off topic. [pmid: 17701638].
544 Lee A, Joynt GM, Ho AMH, et al. Tips for teachers of evidence-based medicine: making sense of decision analysis using a decision tree. Journal of General Internal Medicine. May. 2009;24(5):642-8. Off topic. [pmid: 19247720].
545 Lee HY, Park EC, Kim HJ, et al. Cost utility analysis of cochlear implants in Korea using different measures of utility. Acta Oto Laryngologica. Aug. 2006;126(8):817. Statistical Analysis. [pmid: 16846923].
546 Lee R, Li PS, Goldstein M, et al. A decision analysis of treatments for obstructive azoospermia. Human Reproduction. Sep. 2008;23(9):2043. Costs only. [pmid: 18556680].
547 Lee YC, Yen AMF, Tai JJ, et al. The effect of metabolic risk factors on the natural course of gastro-oesophageal reflux disease. Gut. Feb. 2009;58(2):174-81. Statistical analysis. [pmid: 18936105].
548 Lee-Huang S, Maiorov V, Huang PL, et al. Structural and functional modeling of human lysozyme reveals a unique nonapeptide, HL9, with anti HIV activity. Biochemistry. Mar. 29. 2005;44(12):4648. Off topic. [pmid: 15779891].
549 Lees J, Yeats C, Redfern O, et al. Gene3D: merging structure and function for a Thousand genomes. Nucleic Acids Research. Jan. 2010;38(Database issue):D296-300. Off topic. [pmid: 19906693].
550 Lehman EM, Wilson ML. Epidemic hepatitis C virus infection in Egypt: estimates of past incidence and future morbidity and mortality. Journal of Viral Hepatitis. Sep. 2009;16(9):650-8. Statistical analysis. [pmid: 19413698].
551 Leichter S. Is the use of insulin analogues cost effective?. Advances in Therapy. Apr. 2008;25(4):285. Review. [pmid: 18414816].
552 Lemey P, Rambaut A, Drummond AJ, et al. Bayesian phylogeography finds its roots. PLoS Computational Biology. Sep. 2009;5(9):e1000520. Off topic. [pmid: 19779555].
553 Lerner EB, Maio RF, Garrison HG, et al. Economic value of out of hospital emergency care: a structured literature review. Annals of Emergency Medicine. Jun. 2006;47(6):515. Review. [pmid: 16713777].
554 Leunen K, Gevaert O, Daemen A, et al. Recurrent copy number alterations in BRCA1-mutated ovarian tumors alter biological pathways. Human Mutation. Dec. 2009;30(12):1693-702. Off topic. [pmid: 19802895].
555 Levin P. The cost effectiveness of insulin glargine vs. neutral protamine Hagedorn insulin in type 2 diabetes: a focus on health economics. Diabetes, obesity & metabolism. Jul. 2008;10(Suppl 2):66. Review.
556 Levitan B, Yee CL, Russo L, et al. A model for decision support in signal triage. Drug Safety. 2008;31(9):727. Off topic. [pmid: 18707187].
557 Li H, Apostolakis GE, Gifun J, et al. Ranking the risks from multiple hazards in a small community. Risk Analysis. Mar. 2009;29(3):438-56. Off topic. [pmid: 19076325].
558 Li H, Ung CY, Ma XH, et al. Simulation of crosstalk between small GTPase RhoA and EGFR-ERK signaling pathway via MEKK1. Bioinformatics. Feb. 1. 2009;25(3):358-64. Off topic. [pmid: 19074159].
559 Li YS, Zhao ZY, Ellis M, et al. Applications and outcomes of periodic epidemiological surveys for schistosomiasis and related economic evaluation in the People's Republic of China. Acta Tropica. Nov-Dec. 2005;96(2 3):266. Off topic. [pmid: 16202595].
560 Lichtenberg FR. The impact of new drug launches on longevity: evidence from longitudinal, disease level data from 52 countries, 1982 2001. International Journal of Health Care Finance & Economics. Mar. 2005;5(1):47. Statistical Analysis. [pmid: 15714263].
561 Lichter PR. Cost effectiveness. Ophthalmology. author reply 1853. Oct. 2008;115(10):1852. Comment letter. [pmid: 18929170].
562 Lieu TA, Ortega-Sanchez I, Ray GT, et al. Community and patient values for preventing herpes zoster. PharmacoEconomics. 2008;26(3):235. Statistical analysis. [pmid: 18282017].
563 Lightfoot G, Barker F, Belcher K, et al. The derivation of optimum criteria for use in the monothermal caloric screening test. Ear & Hearing. Feb. 2009;30(1):54-62. Off topic. [pmid: 19125027].
564 Liljas B, Karlsson GS, Stalhammar NO. On future non medical costs in economic evaluations. Health economics. May. 2008;17(5):579. Off topic. [pmid: 17787027].
565 Lindgren P, Jonsson B. From 4S to IDEAL: the health economics of the statin trials. European Journal of Cardiovascular Prevention & Rehabilitation. Apr. 2009;16(2):138. Off topic. [pmid: 19378393].
566 Lindsay R, Burge RT, Strauss DM. One year outcomes and costs following a vertebral fracture. Osteoporosis International. Jan. 2005;16(1):78. Off topic. [pmid: 15167988].
567 Link RE, Allaf ME, Pili R, et al. Modeling the cost of management options for stage I nonseminomatous germ cell tumors: a decision tree analysis. Journal of Clinical Oncology. Aug. 20. 2005;23(24):5762. Cost Only. [pmid: 16110033].
568 Lips P, van Schoor NM. Quality of life in patients with osteoporosis. Osteoporosis International. May. 2005;16(5):447. Off topic. [pmid: 15609073].
569 Lipshitz R, Cohen MS. Warrants for prescription: analytically and empirically based approaches to improving decision making. Human factors. 2005;47(1):102. Off topic. [pmid: 15960090].
570 Liu L, Rettenmaier AJ, Saving TR. Longevity bias in cost effectiveness analysis. Health economics. Apr. 2008;17(4):523. Off topic. [pmid: 17990284].
571 Liu WC, Doong JL, Tsai SL, et al. Integrated model of simulated occupant injury risk and real medical costs. Journal of Safety Research. 2009;40(6):461-8. Off topic. [pmid: 19945560].
572 Llanos A, Hertrampf E, Cortes F, et al. Cost effectiveness of a folic acid fortification program in Chile. Health Policy. Oct. 2007;83(23):295. Statistical Analysis. [pmid: 17363103].
573 Lo IJ, Lefkowitch JH, Feirt N, et al. Utility of liver allograft biopsy obtained at procurement. Liver Transplantation. May. 2008;14(5):639. Off topic. [pmid: 18324657].
574 Lohmander S, Mazieres B, Martin-Mola E, Pavelka K, Pendleton A, Punzi L, Swoboda B, Varatojo R, Verbruggen G, Zimmermann-Gorska I, Dougados M, EULAR Standing Committee for International Clinical Studies Including Therapeutics (ESCISIT). EULAR evidence based recommendations for the management of hip osteoarthritis: report of a task force of the EULAR Standing Committee for International Clinical Studies Including Therapeutics (ESCISIT). Annals of the Rheumatic Diseases. May. 2005;64(5):669. Off topic. [pmid: 15471891].
575 Lojander J, Rasanen P, Sintonen H, et al. Effect of nasal continuous positive airway pressure therapy on health related quality of life in sleep apnoea patients treated in the routine clinical setting of a university hospital. Journal of International Medical Research. Jul Aug. 2008;36(4):760. Statistical analysis. [pmid: 18652772].
576 Longo C, Upchurch GR Jr. Abdominal aortic aneurysm screening: recommendations and controversies. Vascular & Endovascular Surgery. May-Jun. 2005;39(3):213. Off topic. [pmid: 15920649].
577 Lonini L, Dipietro L, Zollo L, et al. An internal model for acquisition and retention of motor learning during arm reaching. Neural Computation. Jul. 2009;21(7):2009-27. Off topic. [pmid: 19323640].
578 Lonning PE, Geisler J. Aromatase inhibitors socioeconomical issues. Journal of Steroid Biochemistry & Molecular Biology. Aug Sep. 2007;106(1 5):55. Off topic. [pmid: 17604616].
579 Lopez AD, Mathers CD, Ezzati M, et al. Global and regional burden of disease and risk factors, 2001: systematic analysis of population health data. Lancet. May. 27. 2006;367(9524):1747. Off topic. [pmid: 16731270].
580 Lopez-Gigosos R, Garcia-Fortea P, Calvo MJ, et al. Effectiveness and economic analysis of the whole cell/recombinant B subunit (WC/rbs) inactivated oral cholera vaccine in the prevention of traveller's diarrhoea. BMC Infectious Diseases. 2009;9:65. Off topic. [pmid: 19445712].
581 Lopman BA, Nyamukapa C, Hallett TB, et al. Role of widows in the heterosexual transmission of HIV in Manicaland, Zimbabwe, 1998-2003. Sexually Transmitted Infections. Apr. Suppl 1. 2009;85:i41-8. Off topic. [pmid: 19307340].
582 Lotz TF, Chase JG, McAuley KA, et al. Monte Carlo analysis of a new model based method for insulin sensitivity testing. Computer Methods & Programs in Biomedicine. Mar. 2008;89(3):215. Off topic. [pmid: 18242418].
583 Loubiere S, el Filal KM, Sodqi M, et al. When to initiate highly active antiretroviral therapy in low resource settings: the Moroccan experience. Antiviral Therapy. 2008;13(2):241. Statistical analysis. [pmid: 18505175].
584 Loveman E, Turner D, Hartwell D, et al. Infliximab for the treatment of adults with psoriasis. Health technology assessment (Winchester, England). Jun. 2009;13(Suppl 1):55. Review.
585 Lovrics PJ, Cornacchi SD, Barnabi F, et al. The feasibility and responsiveness of the health utilities index in patients with early stage breast cancer: a prospective longitudinal study. Quality of Life Research. Mar. 2008;17(2):333. Off topic. [pmid: 18224459].
586 Lovvorn JR, Grebmeier JM, Cooper LW, et al. Modeling marine protected areas for threatened eiders in a climatically changing Bering Sea. Ecological Applications. Sep. 2009;19(6):1596-613. Off topic. [pmid: 19769106].
587 Lu B, Wu Y, Nielson CM, et al. Factors associated with acquisition and clearance of human papillomavirus infection in a cohort of US men: a prospective study. Journal of Infectious Diseases. Feb. 1. 2009;199(3):362-71. Off topic. [pmid: 19133808].
588 Lu DV, Brown RH, Arumugam M, et al. Pairagon: a highly accurate, HMM-based cDNA-to-genome aligner. Bioinformatics. Jul. 1. 2009;25(13):1587-93. Off topic. [pmid: 19414532].
589 Luengo-Fernandez R, Gray AM, Rothwell PM. Costs of stroke using patient-level data: a critical review of the literature. Stroke. Feb. 2009;40(2):e18. Review. [pmid: 19109540].
590 Lundkvist J, Steffen R, Jonsson B. Cost-benefit of WC/rBS oral cholera vaccine for vaccination against ETEC-caused travelers' diarrhea. [Erratum appears in J Travel Med. 2009 Mar-Apr;16(2):147]. Journal of Travel Medicine. Jan-Feb. 2009;16(1):28-34. Costs only. [pmid: 19192125].
591 Lurie SJ, Nofziger AC, Meldrum S, et al. Temporal and group related trends in peer assessment amongst medical students. Medical education. Sep. 2006;40(9):840. Off topic. [pmid: 16925633].
592 Lutumba P, Makieya E, Shaw A, et al. Human African trypanosomiasis in a rural community, Democratic Republic of Congo. Emerging Infectious Diseases. Feb. 2007;13(2):248. Off topic. [pmid: 17479887].
593 Lyman GH, Cosler LE, Kuderer NM, et al. Impact of a 21 gene RT PCR assay on treatment decisions in early stage breast cancer: an economic analysis based on prognostic and predictive validation studies. Cancer. Mar. 15. 2007;109(6):1011. Statistical Analysis. [pmid: 17311307].
594 Lynd LD, Goeree R, O'Brien BJ. Antiviral agents for influenza: a comparison of cost effectiveness data. PharmacoEconomics. 2005;23(11):1083. Review. [pmid: 16277546].
595 Lyseng-Williamson KA, Plosker GL. Clopidogrel: a pharmacoeconomic review of its use in patients with non ST elevation acute coronary syndromes. PharmacoEconomics. 2006;24(7):709. Review. [pmid: 16802846].
596 Ma G, Jin Y, Li Y, et al. Iron and zinc deficiencies in China: what is a feasible and cost effective strategy?. Public health nutrition. Jun. 2008;11(6):632. Off topic. [pmid: 17894916].
597 Mabasa VH, Taylor SC. Re evaluation of the cost effectiveness of temozolomide for malignant gliomas in British Columbia. Journal of Oncology Pharmacy Practice. Jun. 2006;12(2):105. Statistical Analysis. [pmid: 16984749].
598 Mabasa VH, Taylor SC, Chu CC, et al. Verification of imatinib cost effectiveness in advanced gastrointestinal stromal tumor in British Columbia (VINCE BC study). Journal of Oncology Pharmacy Practice. Sep. 2008;14(3):105. Statistical analysis. [pmid: 18524863].
599 Maciosek MV, Coffield AB, Edwards NM, et al. Priorities among effective clinical preventive services: results of a systematic review and analysis. American Journal of Preventive Medicine. Jul. 2006;31(1):52. Off topic. [pmid: 16777543].
600 Maggioni A, Minig L, Zanagnolo V, et al. Robotic approach for cervical cancer: comparison with laparotomy: a case control study. Gynecologic Oncology. Oct. 2009;115(1):60-4. Statistical analysis. [pmid: 19638333].
601 Maguire LA. Re: Uses and misuses of multicriteria decision analysis (MCDA) in environmental decision making. Risk Analysis. Nov. 2009;29(11):1493. author reply 4. No abstract. [pmid: 19886943].
602 Mahan ST, Katz JN, Kim YJ. To screen or not to screen? A decision analysis of the utility of screening for developmental dysplasia of the hip. Journal of Bone & Joint Surgery American Volume. Jul. 2009;91(7):1705. Decision aid.
603 Mahle WT, Forbess JM, Kirshbom PM, et al. Cost utility analysis of salvage cardiac extracorporeal membrane oxygenation in children. Journal of Thoracic & Cardiovascular Surgery. May. 2005;129(5):1084. Statistical Analysis. [pmid: 15867784].
604 Malmstrom PU, Hedelin H, Thomas YK, et al. Fluorescence-guided transurethral resection of bladder cancer using hexaminolevulinate: analysis of health economic impact in Sweden. Scandinavian Journal of Urology & Nephrology. 2009;43(3):192. Cost Only. [pmid: 19330681].
605 Manca A, Hawkins N, Sculpher MJ. Estimating mean QALYs in trial based cost effectiveness analysis: the importance of controlling for baseline utility. Health economics. May. 2005;14(5):487. Off topic. [pmid: 15497198].
606 Manca A, Rice N, Sculpher MJ, et al. Assessing generalisability by location in trial based cost effectiveness analysis: the use of multilevel models. Health economics. May. 2005;14(5):471. Off topic. [pmid: 15386662].
607 Mancino MJ, Pyne JM, Tripathi S, et al. Quality adjusted health status in veterans with posttraumatic stress disorder. Journal of Nervous & Mental Disease. Nov. 2006;194(11):877. Off topic. [pmid: 17102715].
608 Mangham LJ, Petrou S, Doyle LW, et al. The cost of preterm birth throughout childhood in England and Wales. Pediatrics. Feb. 2009;123(2):e312. Cost Only. [pmid: 19171583].
609 Mann RD. Multi criteria decision analysis a new approach to an old problem. Pharmacoepidemiology & Drug Safety. Jul. 2007;16(Suppl 1):S1. Cost only. [pmid: 17582813].
610 Mannan HR, Knuiman M, Hobbs M. A Markov simulation model for analyzing and forecasting the number of coronary artery revascularization procedures in Western Australia. Annals of Epidemiology. Dec. 2007;17(12):964. Off topic. [pmid: 18022536].
611 Mannan HR, Knuiman M, Hobbs M. Adapting a Markov Monte Carlo simulation model for forecasting the number of coronary artery revascularisation procedures in an era of rapidly changing technology and policy. BMC Medical Informatics & Decision Making. 2008;8:27. Off topic. [pmid: 18578858].
612 Mansdotter A, Lindholm L, Winkvist A. Paternity leave in Sweden: costs, savings and health gains. Health Policy. Jun. 2007;82(1):102. Statistical Analysis. [pmid: 17046098].
613 Mansdotter AM, Rydberg MK, Wallin E, et al. A cost effectiveness analysis of alcohol prevention targeting licensed premises. European journal of public health. Dec. 2007;17(6):618. Statistical Analysis. [pmid: 17387105].
614 Man-Son-Hing M, Gage BF, Montgomery AA, et al. Preference based antithrombotic therapy in atrial fibrillation: implications for clinical decision making. Medical Decision Making. Sep-Oct. 2005;25(5):548. Review. [pmid: 16160210].
615 Mansour AA 3rd, Even JL, Phillips S, et al. Eye protection in orthopaedic surgery. An in vitro study of various forms of eye protection and their effectiveness. Journal of Bone & Joint Surgery American Volume. May. 2009;91(5):1050-4. Off topic.
616 Mansueto M, Grimaldi A, Torbica A, et al. Cost effectiveness analysis in the clinical management of patients with known or suspected lung cancer: 18F fluorodeoxyglucose PET and CT comparison. The Quarterly Journal of Nuclear Medicine & Molecular Imaging. Sep. 2007;51(3):224. Statistical Analysis. [pmid: 17538525].
617 Mant J, Doust J, Roalfe A, et al. Systematic review and individual patient data meta-analysis of diagnosis of heart failure, with modelling of implications of different diagnostic strategies in primary care. Health technology assessment (Winchester, England). Jul. 2009;13(32):iii. 1. Review.
618 Marchevsky AM. The application of special technologies in diagnostic anatomic pathology: is it consistent with the principles of evidence based medicine?. Seminars in diagnostic pathology. May. 2005;22(2):156. Off topic. [pmid: 16639994].
619 Marchionni L, Wilson RF, Marinopoulos SS, et al. Impact of gene expression profiling tests on breast cancer outcomes. Evidence Report/Technology Assessment. Dec. 2007;(160):1. Off topic. [pmid: 18457476].
620 Marion A, Vray D. Toward a real-time simulation of ultrasound image sequences based on a 3-D set of moving scatterers. IEEE Transactions on Ultrasonics Ferroelectrics & Frequency Control. Oct. 2009;56(10):2167-79. Off topic.
621 Marmor S, Farman T, Lortat-Jacob A. Joint infection after knee arthroscopy: medicolegal aspects. Orthopaedics & traumatology, surgery & research. Jun. 2009;95(4):278. Off topic.
622 Marra CA, Rashidi AA, Guh D, et al. Are indirect utility measures reliable and responsive in rheumatoid arthritis patients?. Quality of Life Research. Jun. 2005;14(5):1333. Off topic. [pmid: 16047508].
623 Marra CA, Woolcott JC, Kopec JA, et al. A comparison of generic, indirect utility measures (the HUI2, HUI3, SF 6D, and the EQ 5D) and disease specific instruments (the RAQoL and the HAQ) in rheumatoid arthritis. Social science & medicine. Apr. 2005;60(7):1571. Off topic. [pmid: 15652688].
624 Marseille E, Dandona L, Marshall N, et al. HIV prevention costs and program scale: data from the PANCEA project in five low and middle income countries. BMC Health Services Research. 2007;7:108. Statistical Analysis. [pmid: 17626616].
625 Marshall DA, Hux M. Design and analysis issues for economic analysis alongside clinical trials. Medical care. Jul. 2009;47(7 Suppl 1):S14. Off topic. [pmid: 19536012].
626 Masaki T, Matsuoka H, Sugiyama M, et al. Actual number of tumor budding as a new tool for the individualization of treatment of T1 colorectal carcinomas. Journal of Gastroenterology & Hepatology. Jul. 2006;21(7):1115. Off topic. [pmid: 16824062].
627 Masaki T, Matsuoka H, Sugiyama M, et al. Tumor budding and evidence based treatment of T2 rectal carcinomas. Journal of surgical oncology. Oct. 1. 2005;92(1):59. Off topic. [pmid: 16180229].
628 Mastracci TM, Thoma A, Farrokhyar F, et al. Users' guide to the surgical literature: how to use a decision analysis. Canadian Journal of Surgery. Oct. 2007;50(5):403. Cost only.
629 Matza LS, Secnik K, Rentz AM, et al. Assessment of health state utilities for attention deficit/hyperactivity disorder in children using parent proxy report. Quality of Life Research. Apr. 2005;14(3):735. Off topic. [pmid: 16022066].
630 Maud A, Lakshminarayan K, Suri MF, et al. Cost-effectiveness analysis of endovascular versus neurosurgical treatment for ruptured intracranial aneurysms in the United States. Journal of neurosurgery. May. 2009;110(5):880. Off topic. [pmid: 19199452].
631 Mauskopf J, Flynn M, Thieda P, et al. The economic impact of uterine fibroids in the United States: a summary of published estimates. Journal of Women's Health. Oct. 2005;14(8):692. Review.
632 Mbonye AK, Hansen KS, Bygbjerg IC, et al. Intermittent preventive treatment of malaria in pregnancy: the incremental cost effectiveness of a new delivery system in Uganda. Transactions of the Royal Society of Tropical Medicine & Hygiene. Jul. 2008;102(7):685. Off topic. [pmid: 18513767].
633 McCabe C, Claxton K, Culyer AJ. The NICE cost effectiveness threshold: what it is and what that means. PharmacoEconomics. 2008;26(9):733. Off topic. [pmid: 18767894].
634 McClamroch KJ, Kaufman JS, Behets FM. A formal decision analysis identifies an optimal treatment strategy in a resource poor setting. Journal of clinical epidemiology. Aug. 2008;61(8):776. Off topic. [pmid: 18342487].
635 McCormack PL, Foster RH. Rizatriptan: a pharmacoeconomic review of its use in the acute treatment of migraine. PharmacoEconomics. 2005;23(12):1283. Review. [pmid: 16336021].
636 McDaid C, Griffin S, Weatherly H, et al. Continuous positive airway pressure devices for the treatment of obstructive sleep apnoea-hypopnoea syndrome: a systematic review and economic analysis. Health technology assessment (Winchester, England). 1. 119. 143. 274. Jan. 2009;13(4):xi-xiv. iii. Statistical Analysis.
637 McDonald WM. Is ECT cost effective? A critique of the National Institute of Health and Clinical Excellence's report on the economic analysis of ECT. Journal of ECT. Mar. 2006;22(1):25. Review. [pmid: 16633202].
638 McDonough P, Worts D, Sacker A. Socioeconomic inequalities in health dynamics: a comparison of Britain and the United States. Social Science & Medicine. Jan. 2010;70(2):251-60. Off topic. [pmid: 19857919].
639 McGregor M, Caro JJ. QALYs: are they helpful to decision makers?. PharmacoEconomics. 2006;24(10):947. Off topic. [pmid: 17002477].
640 McGrory BJ, Bal BS, York S, et al. Surgeon demographics and medical malpractice in adult reconstruction. Clinical Orthopaedics & Related Research. Feb. 2009;467(2):358. Off topic. [pmid: 18989734].
641 McIntosh MS, Konzelmann J, Smith J, et al. Stabilization and treatment of dental avulsions and fractures by emergency physicians using just-in-time training. Annals of Emergency Medicine. Oct. 2009;54(4):585-92. Off topic. [pmid: 19700221].
642 McIntyre JD, Lee JY, Trope M, et al. Management of avulsed permanent incisors: a comprehensive update. Pediatric dentistry. Jan Feb. 2007;29(1):56. Review. [pmid: 18041514].
643 McIntyre JD, Lee JY, Trope M, et al. Permanent tooth replantation following avulsion: using a decision tree to achieve the best outcome. Pediatric dentistry. Mar-Apr. 2009;31(2):137. Decision aid. [pmid: 19455933].
644 McKeage K, Lyseng-Williamson KA. Trastuzumab: a pharmacoeconomic review of its use in early breast cancer. PharmacoEconomics. 2008;26(8):699. Review. [pmid: 18620462].
645 McKeage K, Perry CM, Keam SJ. Darunavir: a review of its use in the management of HIV infection in adults. Drugs. 2009;69(4):477. Off topic. [pmid: 19323590].
646 McKenna SP, Ratcliffe J, Meads DM, et al. Development and validation of a preference based measure derived from the Cambridge Pulmonary Hypertension Outcome Review (CAMPHOR) for use in cost utility analyses. Health & Quality of Life Outcomes. 2008;6:65. Off topic. [pmid: 18718016].
647 McLeod C, Bagust A, Boland A, et al. Erlotinib for the treatment of relapsed non-small cell lung cancer. Health technology assessment (Winchester, England). Jun. 2009;13(Suppl 1):41. Review.
648 McLeod C, Fleeman N, Kirkham J, et al. Deferasirox for the treatment of iron overload associated with regular blood transfusions (transfusional haemosiderosis) in patients suffering with chronic anaemia: a systematic review and economic evaluation. Health technology assessment (Winchester, England). 1. 121. Jan. 2009;13(1):ix-xi. iii. Review.
649 McLeod R, Phang T, Wexner S, et al. Canadian Association of General Surgeons and American College of Surgeons evidence based reviews in surgery. 17. The timing of elective colectomy in diverticulitis: a decision analysis. Canadian Journal of Surgery. Jun. 2006;49(3):212. Cost only.
650 McNamee P, Seymour J. Incorporation of process preferences within the QALY framework: a study of alternative methods. Medical Decision Making. May Jun. 2008;28(3):443. Off topic. [pmid: 18356313].
651 Melloh M, Roder C, Elfering A, et al. Differences across health care systems in outcome and cost utility of surgical and conservative treatment of chronic low back pain: a study protocol. BMC Musculoskeletal Disorders. 2008;9:81. Statistical analysis. [pmid: 18534034].
652 Menendez R, Reyes S, Martinez R, et al. Economic evaluation of adherence to treatment guidelines in nonintensive care pneumonia. European Respiratory Journal. Apr. 2007;29(4):751. Statistical Analysis. [pmid: 17005580].
653 Meng W, Yu F, Chen H, et al. Concentration polarization of high-density lipoprotein and its relation with shear stress in an in vitro model. Journal of Biomedicine & Biotechnology. 2009;2009:695838. Off topic. [pmid: 19753319].
654 Menzin J, Sussman M, Tafesse E, et al. A model of the economic impact of a bipolar disorder screening program in primary care. Journal of Clinical Psychiatry. Sep. 2009;70(9):1230-6. Costs only. [pmid: 19689919].
655 Middleton DB, Lin CJ, Smith KJ, et al. Economic evaluation of standing order programs for pneumococcal vaccination of hospitalized elderly patients. Infection Control & Hospital Epidemiology. May. 2008;29(5):385. Decision aid. [pmid: 18521990].
656 Middleton J, Vaks JE. Evaluation of assigned value uncertainty for complex calibrator value assignment processes: a prealbumin example. Clinical chemistry. Apr. 2007;53(4):735. Off topic. [pmid: 17303686].
657 Milcent C, Dormont B, Durand-Zaleski I, et al. Gender differences in hospital mortality and use of percutaneous coronary intervention in acute myocardial infarction: microsimulation analysis of the 1999 nationwide French hospitals database. Circulation. Feb. 20. 2007;115(7):833. Off topic. [pmid: 17309933].
658 Mileman PA, van den Hout WB. Evidence-based diagnosis and clinical decision making. Dento-Maxillo-Facial Radiology. Jan. 2009;38(1):1. Off topic. [pmid: 19114417].
659 Miller PS, Andersson FL, Kalra L. Are cost benefits of anticoagulation for stroke prevention in atrial fibrillation underestimated?. Stroke. Feb. 2005;36(2):360. Off topic. [pmid: 15637326].
660 Miller W. The significance of using US Valued EQ 5D health states for comparative effectiveness and cost effectiveness studies in US populations. Medical Decision Making. May Jun. 2007;27(3):229. Cost only. [pmid: 17545493].
661 Miners A. Estimating ‘costs’ for cost effectiveness analysis. PharmacoEconomics. 2008;26(9):745. Off topic. [pmid: 18767895].
662 Mittmann N, Au HJ, Tu D, et al. Journal of the National Cancer Institute. Sep. 2. 2009;101(17):1182. Statistical Analysis. [pmid: 19666851].
663 Mittmann N, Craven BC, Gordon M, et al. Erectile dysfunction in spinal cord injury: a cost utility analysis. Journal of Rehabilitation Medicine. Nov. 2005;37(6):358. Off topic. [pmid: 16287667].
664 Miyazaki Y, Harada T, Akase T, et al. Cost-minimization analysis of sequence changes between FOLFIRI and FOLFOX6 therapy for advanced colorectal cancer in Japan. Clinical Therapeutics. 2009;31 Pt 2:2433-41. Costs only. [pmid: 20110051].
665 Moayyedi P. The health economics of Helicobacter pylori infection. Best Practice & Research in Clinical Gastroenterology. 2007;21(2):347. Off topic.
666 Moayyedi P. Economic reflections on proton pump inhibitor therapy for non erosive reflux disease. Digestion. 2008;78(Suppl 1):61. Review. [pmid: 18832842].
667 Mol F, Strandell A, Jurkovic D, et al. BMC Women's Health. 2008;8:11. Off topic. [pmid: 18582372].
668 Molinari M, Helton S. Hepatic resection versus radiofrequency ablation for hepatocellular carcinoma in cirrhotic individuals not candidates for liver transplantation: a Markov model decision analysis. American Journal of Surgery. Sep. 2009;198(3):396. Decision aid. [pmid: 19520354].
669 Montgomery AA, Emmett CL, Fahey T, et al. Two decision aids for mode of delivery among women with previous caesarean section: randomised controlled trial. Bmj. Jun. 23. 2007;334(7607):1305. Statistical Analysis. [pmid: 17540908].
670 Mooney A. Quality of life: questionnaires and questions. Journal of health communication. Apr-May. 2006;11(3):327. Off topic. [pmid: 16624797].
671 Moore DE, Speroff T, Grogan E, et al. Cost perspectives of laparoscopic and open appendectomy. Surgical endoscopy. Mar. 2005;19(3):374. Cost Only. [pmid: 15624056].
672 Moore DF, Ries M, Forget EL, et al. Enzyme replacement therapy in orphan and ultra orphan diseases: the limitations of standard economic metrics as exemplified by Fabry Anderson disease. PharmacoEconomics. 2007;25(3):201. Statistical Analysis. [pmid: 17335306].
673 Moore TJ, Ritter A, Caulkins JP. The costs and consequences of three policy options for reducing heroin dependency. Drug & Alcohol Review. Jul. 2007;26(4):369. Cost Only. [pmid: 17564872].
674 Morris M, Kurth AE, Hamilton DT, et al. Concurrent partnerships and HIV prevalence disparities by race: linking science and public health practice. American Journal of Public Health. Jun. 2009;99(6):1023-31. Off topic. [pmid: 19372508].
675 Moss AC, Morris E, Leyden J, et al. Do the benefits of metal stents justify the costs? A systematic review and meta analysis of trials comparing endoscopic stents for malignant biliary obstruction. European journal of gastroenterology & hepatology. Dec. 2007;19(12):1119. Review. [pmid: 17998839].
676 Mueller C. Cost effectiveness of B type natriuretic peptide testing. Congestive Heart Failure. Jul Aug. 2008;14(4 Suppl 1):35. Review. [pmid: 18772637].
677 Muhlberger N, Sroczynski G, Esteban E, et al. Cost effectiveness of primarily human papillomavirus based cervical cancer screening in settings with currently established Pap screening: a systematic review commissioned by the German Federal Ministry of Health. International Journal of Technology Assessment in Health Care. 2008;24(2):184. Review. [pmid: 18400122].
678 Munoz-Duyos A, Navarro-Luna A, Brosa M, et al. Clinical and cost effectiveness of sacral nerve stimulation for faecal incontinence. British Journal of Surgery. Aug. 2008;95(8):1037. Off topic. [pmid: 18574847].
679 Murphy SP, Burkom H. Recombinant temporal aberration detection algorithms for enhanced biosurveillance. Journal of the American Medical Informatics Association. Jan Feb. 2008;15(1):77. Off topic. [pmid: 17947614].
680 Murray D. Decision making and decision analysis. Anaesthesia. Nov. 2006;61(11):1119. Cost only. [pmid: 17042860].
681 Mushlin AI, Kern LM, Paris M, et al. The value of diagnostic information to patients with chest pain suggestive of coronary artery disease. Medical Decision Making. Mar-Apr. 2005;25(2):149. Statistical Analysis. [pmid: 15800299].
682 Mussen F, Salek S, Walker S. A quantitative approach to benefit risk assessment of medicines part 1: the development of a new model using multi criteria decision analysis. Pharmacoepidemiology & Drug Safety. Jul. 2007;16(Suppl 1):S2. Off topic. [pmid: 17546573].
683 Mussen F, Salek S, Walker S. A quantitative approach to benefit risk assessment of medicines part 1: the development of a new model using multi criteria decision analysis;part 2: the practical application of a new model. Pharmacoepidemiology & Drug Safety. Jul. 2007;16(Suppl 1):S42. Cost only. [pmid: 17546572].
684 Myers J, McCabe SJ. Understanding medical decision making in hand surgery. Clinics in plastic surgery. Oct. 2005;32(4):v. 453. Off topic.
685 Na SH, Kim SG. A step function model to evaluate the real monetary value of man-sievert with real GDP. Applied Radiation & Isotopes. Jul-Aug. 2009;67(7-8):1307-10. Off topic. [pmid: 19307131].
686 Nadler E, Eckert B, Neumann PJ. Do oncologists believe new cancer drugs offer good value?. Oncologist. Feb. 2006;11(2):90. Off topic. [pmid: 16476830].
687 Nafar M, Mousavi SM, Mahdavi-Mazdeh M, et al. Burden of chronic kidney disease in Iran: a screening program is of essential need. Iranian journal of Kidney Diseases. Oct. 2008;2(4):183. Off topic. [pmid: 19377235].
688 Nan L, Johnson JA, Shaw JW, et al. A comparison of EQ 5D index scores derived from the US and UK population based scoring functions. Medical Decision Making. May Jun. 2007;27(3):321. Off topic. [pmid: 17545501].
689 Nannan N, Norman R, Hendricks M, et al. Estimating the burden of disease attributable to childhood and maternal undernutrition in South Africa in 2000. South African Medical Journal.Suid Afrikaanse Tydskrif Vir Geneeskunde. Aug. 2007;97(8 Pt 2):733. Off topic. [pmid: 17952231].
690 Narumi D, Kondo A, Shimoda Y. Effects of anthropogenic heat release upon the urban climate in a Japanese megacity. Environmental Research. May. 2009;109(4):421-31. Off topic. [pmid: 19349044].
691 Neidecker MV, Davis-Ajami ML, Balkrishnan R, et al. Pharmacoeconomic considerations in treating actinic keratosis. Pharmacoeconomics. 2009;27(6):451-64. Review. [pmid: 19640009].
692 Neovius M, Narbro K. Cost effectiveness of pharmacological anti obesity treatments: a systematic review. International journal of obesity. Dec. 2008;32(12):1752. Review. [pmid: 18982009].
693 Neto JG, de Cleva R, Zilberstein B, et al. Surgical risk for patients with Chagasic achalasia and its correlation with the degree of esophageal dilation. World Journal of Gastroenterology. Oct. 7. 2005;11(37):5840. Statistical Analysis. [pmid: 16270395].
694 Nett IRE, Martin DMA, Miranda-Saavedra D, et al. The phosphoproteome of bloodstream form Trypanosoma brucei, causative agent of African sleeping sickness. Molecular & Cellular Proteomics. Jul. 2009;8(7):1527-38. Off topic. [pmid: 19346560].
695 Neumann PJ. Costing and perspective in published cost-effectiveness analysis. Medical care. Jul. 2009;47(7 Suppl 1):S28. Off topic. [pmid: 19536023].
696 Neumann PJ, Greenberg D, Olchanski NV, et al. Growth and quality of the cost utility literature, 1976 2001. Value in Health. Jan-Feb. 2005;8(1):3. Review. [pmid: 15841889].
697 Neumann PJ, Lin PJ, Greenberg D, et al. Do drug formulary policies reflect evidence of value?. American Journal of Managed Care. Jan. 2006;12(1):30. Review. [pmid: 16402886].
698 Neumann PJ, Rosen AB, Greenberg D, et al. Can we better prioritize resources for cost utility research?. Medical Decision Making. Jul-Aug. 2005;25(4):429. Off topic. [pmid: 16061895].
699 Neyt M, Van Brabandt H, Devriese S, et al. Cost-effectiveness analyses of drug eluting stents versus bare metal stents: a systematic review of the literature. Health Policy. Jul. 2009;91(2):107. Review. [pmid: 19135756].
700 Nickel S, Schmidt UA. Process improvement in hospitals: a case study in a radiology department. Quality Management in Health Care. Oct-Dec. 2009;18(4):326-38. Off topic. [pmid: 19851240].
701 Niederkohr RD, Levin LA. A Bayesian analysis of the true sensitivity of a temporal artery biopsy. Investigative ophthalmology & visual science. Feb. 2007;48(2):675. Off topic. [pmid: 17251465].
702 Nielsen R, Johannessen A, Benediktsdottir B, et al. Present and future costs of COPD in Iceland and Norway: results from the BOLD study. European Respiratory Journal. Oct. 2009;34(4):850-7. Costs only. [pmid: 19357148].
703 Niessen LW, Grijseels E, Koopmanschap M, et al. Economic analysis for clinical practice the case of 31 national consensus guidelines in the Netherlands. Journal of evaluation in clinical practice. Feb. 2007;13(1):68. Off topic. [pmid: 17286726].
704 Niessen LW, ten Hove A, Hilderink H, et al. Comparative impact assessment of child pneumonia interventions. Bulletin of the World Health Organization. Jun. 2009;87(6):472. Statistical Analysis. [pmid: 19565126].
705 Nijhuis RL, Stijnen T, Peeters A, et al. Apparent and internal validity of a Monte Carlo Markov model for cardiovascular disease in a cohort follow up study. Medical Decision Making. Mar-Apr. 2006;26(2):134. Review. [pmid: 16525167].
706 Noble J, Hollands H, Forooghian F, et al. Evaluating the cost effectiveness of anterior uveitis investigation by Canadian ophthalmologists. Canadian Journal of Ophthalmology. Dec. 2008;43(6):652. Costs only. [pmid: 19020630].
707 Noecker RJ, Walt JG. Cost effectiveness of monotherapy treatment of glaucoma and ocular hypertension with the lipid class of medications. American Journal of Ophthalmology. Jan. 2006;141(1 Suppl):S15. Statistical Analysis. [pmid: 16389056].
708 Nojilana B, Norman R, Bradshaw D, et al. Estimating the burden of disease attributable to vitamin A deficiency in South Africa in 2000. South African Medical Journal.Suid Afrikaanse Tydskrif Vir Geneeskunde. Aug. 2007;97(8 Pt 2):748. Off topic. [pmid: 17952233].
709 Nojilana B, Norman R, Dhansay MA, et al. Estimating the burden of disease attributable to iron deficiency anaemia in South Africa in 2000. South African Medical Journal.Suid Afrikaanse Tydskrif Vir Geneeskunde. Aug. 2007;97(8 Pt 2):741. Off topic. [pmid: 17952232].
710 Nord E. Utilitarian decision analysis of informed consent. American Journal of Bioethics. discussion W51-3. May-Jun. 2006;6(3):65. Cost only. [pmid: 16754460].
711 Norman R, Bradshaw D, Steyn K, et al. Estimating the burden of disease attributable to high cholesterol in South Africa in 2000. South African Medical Journal.Suid Afrikaanse Tydskrif Vir Geneeskunde. Aug. 2007;97(8 Pt 2):708. Off topic. [pmid: 17952228].
712 Norman R, Gaziano T, Laubscher R, et al. Estimating the burden of disease attributable to high blood pressure in South Africa in 2000. South African Medical Journal.Suid Afrikaanse Tydskrif Vir Geneeskunde. Aug. 2007;97(8 Pt 2):692. Off topic. [pmid: 17952226].
713 Normand C. Measuring outcomes in palliative care: limitations of QALYs and the road to PalYs. Journal of Pain & Symptom Management. Jul. 2009;38(1):27. Off topic. [pmid: 19615624].
714 Novak EJ, Vail TP, Bozic KJ. Advances in orthopaedic outcomes research. Journal of Surgical Orthopaedic Advances. 2008;17(3):200. Off topic. [pmid: 18851807].
715 O'Brien SH. Decision analysis in pediatric hematology. Pediatric clinics of North America. Apr. 2008;55(2):vii. 287. Off topic.
716 O'Connell JM, Brunson D, Anselmo T, et al. Costs and savings associated with community water fluoridation programs in Colorado. Preventing Chronic Disease. Nov. 2005;2(Speco):A06. Cost Only. [pmid: 16263039].
717 O'Hagan A, Stevenson M, Madan J. Monte Carlo probabilistic sensitivity analysis for patient level simulation models: efficient estimation of mean and variance using ANOVA. Health economics. Oct. 2007;16(10):1009. Off topic. [pmid: 17173339].
718 Ohkusa Y, Sugawara T. Simulation model of pandemic influenza in the whole of Japan. Japanese Journal of Infectious Diseases. Mar. 2009;62(2):98-106. Off topic. [pmid: 19305048].
719 O'Malley SP, Jordan E. Review of a decision by the Medical Services Advisory Committee based on health technology assessment of an emerging technology: the case for remotely assisted radical prostatectomy. International Journal of Technology Assessment in Health Care. 2007;23(2):286. Off topic. [pmid: 17493316].
720 Ong AT, Daemen J, van Hout BA, et al. Cost effectiveness of the unrestricted use of sirolimus eluting stents vs. bare metal stents at 1 and 2 year follow up: results from the RESEARCH Registry. European heart journal. Dec. 2006;27(24):2996. Statistical Analysis. [pmid: 17114234].
721 Onukwugha E, Mullins CD, DeLisle S. Using cost effectiveness analysis to sharpen formulary decision making: the example of tiotropium at the Veterans Affairs health care system. Value in Health. Sep Oct. 2008;11(5):980. Off topic. [pmid: 18194405].
722 Orozco A, Alvarez M, Guijarro E, et al. Identification of spike sources using proximity analysis through hidden Markov models. Conference Proceedings: Annual International Conference of the IEEE Engineering in Medicine & Biology Society. 2006;1:5555. Off topic.
723 Ortega-Sanchez IR, Lee GM, Jacobs RJ, et al. Projected cost effectiveness of new vaccines for adolescents in the United States. Pediatrics. Jan. 2008;121(Suppl 1):S63. Review. [pmid: 18174323].
724 Ortendahl M. Models based on value and probability in health improve shared decision making. Journal of evaluation in clinical practice. Oct. 2008;14(5):714. Off topic. [pmid: 19018900].
725 Oscar TP. General regression neural network and monte carlo simulation model for survival and growth of salmonella on raw chicken skin as a function of serotype, temperature, and time for use in risk assessment. Journal of Food Protection. Oct. 2009;72(10):2078-87. Off topic. [pmid: 19833030].
726 Osiri M, Kamolratanakul P, Maetzel A, et al. Cost effectiveness analysis of disease modifying antirheumatic drugs in rheumatoid arthritis. Rheumatology international. Sep. 2007;27(11):1063. Statistical Analysis. [pmid: 17440729].
727 Owens CD, Ho KJ, Kim S, et al. Refinement of survival prediction in patients undergoing lower extremity bypass surgery: stratification by chronic kidney disease classification. Journal of Vascular Surgery. May. 2007;45(5):944. Statistical Analysis. [pmid: 17391900].
728 Ozawa K, Minami H, Sato H. Clinical trial simulations for dosage optimization of docetaxel in patients with liver dysfunction, based on a log-binominal regression for febrile neutropenia. Yakugaku Zasshi Journal of the Pharmaceutical Society of Japan. Jun. 2009;129(6):749. Off topic. [pmid: 19483418].
729 Ozelo MC, Villaca PR, De Almeida JO, et al. A cost evaluation of treatment alternatives for mild to moderate bleeding episodes in patients with haemophilia and inhibitors in Brazil. Haemophilia. Sep. 2007;13(5):462. Statistical Analysis. [pmid: 17880430].
730 Pacini M, Smith RD, Wilson EC, et al. Home based medication review in older people: is it cost effective?. PharmacoEconomics. 2007;25(2):171. Statistical Analysis. [pmid: 17249858].
731 Paladino JA, Gilliland-Johnson KK, Adelman MH, et al. Pharmacoeconomics of ciprofloxacin plus metronidazole vs. piperacillin tazobactam for complicated intra abdominal infections. Surgical Infections. Jun. 2008;9(3):325. Statistical analysis. [pmid: 18570574].
732 Pan JJ, Nahm M, Wakim P, et al. A centralized informatics infrastructure for the National Institute on Drug Abuse Clinical Trials Network. Clinical Trials. Feb. 2009;6(1):67-75. Off topic. [pmid: 19254937].
733 Pan SL, Wu HM, Yen AM, et al. A Markov regression random effects model for remission of functional disability in patients following a first stroke: a Bayesian approach. Statistics in medicine. Dec. 20. 2007;26(29):5335. Off topic. [pmid: 17676712].
734 Pandey RB, Farmer BL. Residue energy and mobility in sequence to global structure and dynamics of a HIV-1 protease (1DIFA) by a coarse-grained Monte Carlo simulation. Journal of Chemical Physics. Jan. 28. 2009;130(4):044906. Off topic. [pmid: 19191412].
735 Papachristou C, Lin S. Microsatellites versus Single Nucleotide Polymorphisms in confidence interval estimation of disease loci. Genetic epidemiology. Jan. 2006;30(1):3. Off topic. [pmid: 16355404].
736 Papadakis S, Oldridge NB, Coyle D, et al. Economic evaluation of cardiac rehabilitation: a systematic review. European Journal of Cardiovascular Prevention & Rehabilitation. Dec. 2005;12(6):513. Review. [pmid: 16319539].
737 Parkin D, Devlin N. Is there a case for using visual analogue scale valuations in cost utility analysis?. Health economics. Jul. 2006;15(7):653. Off topic. [pmid: 16498700].
738 Parodi K, Ferrari A, Sommerer F, et al. Clinical CT based calculations of dose and positron emitter distributions in proton therapy using the FLUKA Monte Carlo code. Physics in Medicine & Biology. Jun. 21. 2007;52(12):3369. Off topic. [pmid: 17664549].
739 Paschalis T, Sandilos P, Tatsis E, et al. Dosimetric evaluation of a new collimator insert system for stereotactic radiotherapy. British Journal of Radiology. Jun. 2007;80(954):446. Off topic. [pmid: 17151063].
740 Paton NI, Chapman CA, Sangeetha S, et al. Cost and cost effectiveness of antiretroviral therapy for HIV infection in Singapore. International Journal of STD & AIDS. Oct. 2006;17(10):699. Statistical Analysis. [pmid: 17059641].
741 Patten SB. An analysis of data from two general health surveys found that increased incidence and duration contributed to elevated prevalence of major depression in persons with chronic medical conditions. Journal of clinical epidemiology. Feb. 2005;58(2):184. Off topic. [pmid: 15680753].
742 Patten SB, Meadows GM. Population-based service planning for implementation of MBCT: linking epidemiologic data to practice. Psychiatric Services. Nov. 2009;60(11):1540-2. Off topic. [pmid: 19880476].
743 Pearson SD, Rawlins MD. Quality, innovation, and value for money: NICE and the British National Health Service. JAMA. Nov. 23. 2005;294(20):2618. Off topic. [pmid: 16304076].
744 Perreault J, Lavoie J, Painchaud P, et al. Set-up and routine use of a database of 10,555 genotyped blood donors to facilitate the screening of compatible blood components for alloimmunized patients. Vox Sanguinis. Jul. 2009;97(1):61-8. Off topic. [pmid: 19490581].
745 Perret-Guillaume C, Wahl D. Cost effectiveness of ximelagatran for stroke prevention. JAMA. author reply 2861. Jun. 15. 2005;293(23):2860. Cost only. [pmid: 15956626].
746 Petrossian TC, Clarke SG. Multiple Motif Scanning to identify methyltransferases from the yeast proteome. Molecular & Cellular Proteomics. Jul. 2009;8(7):1516-26. Off topic. [pmid: 19351663].
747 Pfeiffer RM, Ryan L, Litonjua A, et al. A case cohort design for assessing covariate effects in longitudinal studies. Biometrics. Dec. 2005;61(4):982. Off topic. [pmid: 16401271].
748 Philips Z, Bojke L, Sculpher M, et al. Good practice guidelines for decision analytic modelling in health technology assessment: a review and consolidation of quality assessment. PharmacoEconomics. 2006;24(4):355. Off topic. [pmid: 16605282].
749 Pickard AS, Wang Z, Walton SM, et al. Are decisions using cost utility analyses robust to choice of SF 36/SF 12 preference based algorithm?. Health & Quality of Life Outcomes. 2005;3:11. Review. [pmid: 15748287].
750 Pignone M. Incorporating decision analysis in decision aids. Medical Decision Making. Sep Oct. 2007;27(5):547. Cost only. [pmid: 17921450].
751 Pinheiro L. Operational research methodology in the general medical rounds. Annals of the Academy of Medicine, Singapore. Jul. 2009;38(7):639-4. Off topic.
752 Piskur P, Sonc M, Cufer T, et al. Pharmacoeconomic aspects of adjuvant anastrozole or tamoxifen in breast cancer: a Slovenian perspective. Anti Cancer Drugs. Jul. 2006;17(6):719. Statistical Analysis. [pmid: 16917219].
753 Plevritis SK. Decision analysis and simulation modeling for evaluating diagnostic tests on the basis of patient outcomes. AJR.American Journal of Roentgenology. Sep. 2005;185(3):581. Cost only. [pmid: 16120903].
754 Plevritis SK, Sigal BM, Salzman P, et al. A stochastic simulation model of U.S. breast cancer mortality trends from 1975 to 2000. Journal of the National Cancer Institute. Monographs. 2006;(36):86. Statistical Analysis. [pmid: 17032898].
755 Plosker GL, Figgitt DP. Linezolid: a pharmacoeconomic review of its use in serious Gram positive infections. PharmacoEconomics. 2005;23(9):945. Review. [pmid: 16153136].
756 Plosker GL, Keam SJ. Candesartan cilexetil: a pharmacoeconomic review of its use in chronic heart failure and hypertension. PharmacoEconomics. 2006;24(12):1249. Review. [pmid: 17129078].
757 Plosker GL, Lyseng-Williamson KA. Memantine: a pharmacoeconomic review of its use in moderate to severe Alzheimer's disease. PharmacoEconomics. 2005;23(2):193. Review. [pmid: 15748093].
758 Plosker GL, Lyseng-Williamson KA. Atorvastatin: a pharmacoeconomic review of its use in the primary and secondary prevention of cardiovascular events. PharmacoEconomics. 2007;25(12):1031. Review. [pmid: 18047388].
759 Pomerance J, Zurakowski D, Fine I. The cost-effectiveness of nonsurgical versus surgical treatment for carpal tunnel syndrome. Journal of Hand Surgery American Volume. Sep. 2009;34(7):1193-200. Statistical analysis.
760 Poon CS. A brief commentary on cost effectiveness analysis in radiologic research. AJR.American Journal of Roentgenology. Nov. 2008;191(5):1320. Off topic. [pmid: 18941063].
761 Postma MJ, Beardsworth P, Wilschut JC. Cost effectiveness of oseltamivir treatment of influenza: a critique of published methods and outcomes. Journal of Medical Economics. 2008;11(4):743. Off topic. [pmid: 19450079].
762 Postma MJ, de Vries R, Welte R, et al. Health economic methodology illustrated with recent work on Chlamydia screening: the concept of extended dominance. Sexually transmitted infections. Apr. 2008;84(2):152. Off topic. [pmid: 18077610].
763 Pothos EM, Busemeyer JR. A quantum probability explanation for violations of ‘rational’ decision theory. Proceedings of the Royal Society of London Series B: Biological Sciences. Jun. 22. 2009;276(1665):2171-8. Off topic.
764 Powell C, Hatt SR. Vision screening for amblyopia in childhood. Cochrane Database of Systematic Reviews. 2009;(3):CD005020. Off topic.
765 Powles JW, Zatonski W, Vander Hoorn S, et al. The contribution of leading diseases and risk factors to excess losses of healthy life in Eastern Europe: burden of disease study. BMC Public Health. 2005;5:116. Off topic. [pmid: 16269084].
766 Price CC. Decision analysis for a new bioethics. American Journal of Bioethics. May-Jun. 2006;6(3):62. Cost only. [pmid: 16754459].
767 Prosser LA, Hammitt JK, Keren R. Measuring health preferences for use in cost utility and cost benefit analyses of interventions in children: theoretical and methodological considerations. PharmacoEconomics. 2007;25(9):713. Off topic. [pmid: 17803331].
768 Puig-Junoy J, Lopez-Valcarcel BG. Economic evaluations of massive HPV vaccination: within-study and between study variations in incremental cost per QALY gained. Preventive medicine. May. 2009;48(5):444. Review. [pmid: 19232368].
769 Pullenayegum EM, Willan AR. Semi parametric regression models for cost effectiveness analysis: improving the efficiency of estimation from censored data. Statistics in medicine. Jul. 30. 2007;26(17):3274. Off topic. [pmid: 17309112].
770 Puri N, Puri V, Dellinger RP. History of technology in the intensive care unit. Critical Care Clinics. Jan. 2009;25(1):185-200. Off topic. [pmid: 19268802].
771 Putnam KG, Bohn RL, Ewenstein BM, et al. A cost minimization model for the treatment of minor bleeding episodes in patients with haemophilia A and high titre inhibitors. Haemophilia. May. 2005;11(3):261. Cost Only. [pmid: 15876272].
772 Pyne JM, Tripathi S, Williams DK, et al. Depression free day to utility weighted score: is it valid?. Medical care. Apr. 2007;45(4):357. Off topic. [pmid: 17496720].
773 Radhakrishnan M, van Gool K, Hall J, et al. Economic evaluation of cystic fibrosis screening: a review of the literature. Health Policy. Feb. 2008;85(2):133. Review. [pmid: 17728003].
774 Raftery JP. Paying for costly pharmaceuticals: regulation of new drugs in Australia, England and New Zealand. Medical Journal of Australia. Jan. 7. 2008;188(1):26. Review. [pmid: 18205559].
775 Raikou M, McGuire A, Colhoun HM, et al. Cost effectiveness of primary prevention of cardiovascular disease with atorvastatin in type 2 diabetes: results from the Collaborative Atorvastatin Diabetes Study (CARDS). Diabetologia. Apr. 2007;50(4):733. Statistical Analysis. [pmid: 17265034].
776 Ramsey S, Willke R, Briggs A, et al. Good research practices for cost effectiveness analysis alongside clinical trials: the ISPOR RCT CEA Task Force report. Value in Health. Sep-Oct. 2005;8(5):521. Off topic. [pmid: 16176491].
777 Ramsey SD, Sullivan SD, Kaplan RM. Cost effectiveness of lung volume reduction surgery. Proceedings of the American Thoracic Society. May. 1. 2008;5(4):406. Review. [pmid: 18453346].
778 Rao RPN, Yadav N, Vahia MN, et al. A Markov model of the Indus script. Proceedings of the National Academy of Sciences of the United States of America. Aug. 18. 2009;106(33):13685-90. Off topic. [pmid: 19666571].
779 Rasanen P, Krootila K, Sintonen H, et al. Cost utility of routine cataract surgery. Health & Quality of Life Outcomes. 2006;4:74. Statistical Analysis. [pmid: 17010185].
780 Rasanen P, Ohman J, Sintonen H, et al. Cost utility analysis of routine neurosurgical spinal surgery. Journal of Neurosurgery Spine. Sep. 2006;5(3):204. Statistical Analysis. [pmid: 16961080].
781 Rasanen P, Roine E, Sintonen H, et al. Use of quality adjusted life years for the estimation of effectiveness of health care: A systematic literature review. International Journal of Technology Assessment in Health Care. 2006;22(2):235. Review. [pmid: 16571199].
782 Rastjoo A, Arabalibeik H. Evaluation of Hidden Markov Model for p300 detection in EEG signal. Studies in Health Technology & Informatics. 2009;142:265-7. Off topic. [pmid: 19377164].
783 Rawlins M, Dillon A. Cost effectiveness considerations at NICE. Lancet. Oct. 11. 2008;372(9646):1302. Comment letter. [pmid: 18929903].
784 Rectenwald JE, Upchurch GR Jr. Impact of outcomes research on the management of vascular surgery patients. Journal of Vascular Surgery. Jun. 2007;45(Suppl A):A131. Off topic. [pmid: 17544034].
785 Reeves M, Harwood B, Creinin M. The challenges of analyzing cost effectiveness with a computer model. Fertility & Sterility. author reply 543-4. Aug. 2005;84(2):543. Cost Only. [pmid: 16084908].
786 Rein DB, Wirth KE, Johnson CA, et al. Estimating quality adjusted life year losses associated with visual field deficits using methodological approaches. Ophthalmic epidemiology. Jul Aug. 2007;14(4):258. Statistical Analysis. [pmid: 17896306].
787 Reiner BI. Quantifying radiation safety and quality in medical imaging, part 1: creating the infrastructure. Journal of the American College of Radiology. Aug. 2009;6(8):558-61. Off topic. [pmid: 19643383].
788 Repetto L, Moeremans K, Annemans L, et al. European guidelines for the management of chemotherapy induced anaemia and health economic aspects of treatment. Cancer treatment reviews. 2006;32(Suppl 2):S5. Off topic. [pmid: 16725267].
789 Resnic FS, Arora N, Matheny M, et al. A cost minimization analysis of the angio seal vascular closure device following percutaneous coronary intervention. American Journal of Cardiology. Mar. 15. 2007;99(6):766. Cost Only. [pmid: 17350361].
790 Reuber M, Burness C, Howlett S, et al. Tailored psychotherapy for patients with functional neurological symptoms: a pilot study. Journal of psychosomatic research. Dec. 2007;63(6):625. Statistical Analysis. [pmid: 18061753].
791 Rheingans RD, Constenla D, Antil L, et al. Economic and health burden of rotavirus gastroenteritis for the 2003 birth cohort in eight Latin American and Caribbean countries. Pan American Journal of Public Health. Apr. 2007;21(4):192. Off topic. [pmid: 17612463].
792 Rheingans RD, Heylen J, Giaquinto C. Economics of rotavirus gastroenteritis and vaccination in Europe: what makes sense?. Pediatric Infectious Disease Journal. Jan. 2006;25(1 Suppl):S48. Off topic. [pmid: 16397429].
793 Richardson G, Hawkins N, McCarthy CJ, et al. Cost effectiveness of a supplementary class based exercise program in the treatment of knee osteoarthritis. International Journal of Technology Assessment in Health Care. 2006;22(1):84. Statistical Analysis. [pmid: 16673684].
794 Richardson J, Peacock SJ, Iezzi A. Do quality-adjusted life years take account of lost income? Evidence from an Australian survey. European Journal of Health Economics. Feb. 2009;10(1):103. Off topic. [pmid: 18458973].
795 Rinfret S, Cohen DJ, Tahami Monfared AA, et al. Cost effectiveness of the sirolimus eluting stent in high risk patients in Canada: an analysis from the C SIRIUS trial. American Journal of Cardiovascular Drugs. 2006;6(3):159. Statistical Analysis. [pmid: 16780389].
796 Rocchi A, Menon D, Verma S, et al. The role of economic evidence in Canadian oncology reimbursement decision making: to lambda and beyond. Value in Health. Jul Aug. 2008;11(4):771. Off topic. [pmid: 18179658].
797 Rodriguez-Luna H, Vargas HE. Management of hepatitis C virus infection in the setting of liver transplantation. Liver Transplantation. May. 2005;11(5):479. Off topic. [pmid: 15838917].
798 Rojnik K, Naversnik K. Gaussian process metamodeling in Bayesian value of information analysis: a case of the complex health economic model for breast cancer screening. Value in Health. Mar Apr. 2008;11(2):240. Off topic. [pmid: 18380636].
799 Romeo R, Byford S, Knapp M. Annotation: Economic evaluations of child and adolescent mental health interventions: a systematic review. Journal of Child Psychology & Psychiatry & Allied Disciplines. Sep. 2005;46(9):919. Review.
800 Rosenberg AL, Tremper KK. Wide variations in the cost effectiveness of critical care. Critical care medicine. Nov. 2006;34(11):2849. Cost only. [pmid: 17053572].
801 Ross H, Powell LM, Bauer JE, et al. Community based youth tobacco control interventions: cost effectiveness of the Full Court Press project. Applied Health Economics & Health Policy. 2006;5(3):167. Statistical Analysis. [pmid: 17132031].
802 Ross T, Rasmussen S, Fazil A, et al. Quantitative risk assessment of Listeria monocytogenes in ready-to-eat meats in Australia. International Journal of Food Microbiology. May. 31. 2009;131(2-3):128-37. Off topic. [pmid: 19327859].
803 Rourke KF, Jordan GH. Primary urethral reconstruction: the cost minimized approach to the bulbous urethral stricture. Journal of Urology. Apr. 2005;173(4):1206. Cost Only. [pmid: 15758749].
804 Roze S, Liens D, Palmer A, et al. A health economic model to determine the long term costs and clinical outcomes of raising low HDL cholesterol in the prevention of coronary heart disease. Current Medical Research & Opinion. Dec. 2006;22(12):2549. Review. [pmid: 17166337].
805 Rueda OM, Diaz-Uriarte R. A response to Yu et al. “A forward backward fragment assembling algorithm for the identification of genomic amplification and deletion breakpoints using high density single nucleotide polymorphism (SNP) array”, BMC Bioinformatics 2007, 8: 145. BMC Bioinformatics. 2007;8:394. Off topic. [pmid: 17939873].
806 Russell LB. Is all cost effectiveness analysis local?. Medical Decision Making. May Jun. 2007;27(3):231. Cost only. [pmid: 17545494].
807 Russell RT, Feurer ID, Wisawatapnimit P, et al. The validity of EQ-5D US preference weights in liver transplant candidates and recipients. Liver Transplantation. Jan. 2009;15(1):88. Off topic. [pmid: 19109831].
808 Rutten-van Molken M, Lee TA. Economic modeling in chronic obstructive pulmonary disease. Proceedings of the American Thoracic Society. Sep. 2006;3(7):630. Off topic. [pmid: 16963546].
809 Saar I. The social costs of alcohol misuse in Estonia. European Addiction Research. 2009;15(1):56-62. Costs only. [pmid: 19052463].
810 Saka G, Kreke JE, Schaefer AJ, et al. Use of dynamic microsimulation to predict disease progression in patients with pneumonia related sepsis. Critical care (London, England). 2007;11(3):R65. Statistical Analysis.
811 Sakthong P. Measurement of clinical effect: utility. Journal of the Medical Association of Thailand. Jun. 2008;91(Suppl 2):S43. Off topic. [pmid: 19253487].
812 Sakthong P, Charoenvisuthiwongs R, Shabunthom R. A comparison of EQ 5D index scores using the UK, US, and Japan preference weights in a Thai sample with type 2 diabetes. Health & Quality of Life Outcomes. 2008;6:71. Off topic. [pmid: 18811935].
813 Salo H, Kilpi T, Sintonen H, et al. Cost effectiveness of influenza vaccination of healthy children. Vaccine. Jun. 5. 2006;24(23):4934. Cost Only. [pmid: 16678945].
814 Sanchez JL, Pereperez SB, Bastida JL, et al. Cost utility analysis applied to the treatment of burn patients in a specialized center. Archives of Surgery. discussion 57. Jan. 2007;142(1):50. Off topic. [pmid: 17224500].
815 Sanelli PC, Gold RL, Greenberg ED, et al. Work-in-progress toward incorporating patients' preferences in practice guidelines for imaging aneurysmal subarachnoid hemorrhage. Academic Radiology. May. 2009;16(5):535. Decision aid. [pmid: 19345893].
816 Sankararaman S, Kimmel G, Halperin E, et al. On the inference of ancestries in admixed populations. Genome research. Apr. 2008;18(4):668. Off topic. [pmid: 18353809].
817 Santori G, Valente R, Andorno E, et al. Application of a Bayesian simulation model to a database for split liver transplantation on two adult recipients in the environment of WinBUGS (Bayesian Inference Using Gibbs Sampling). Transplantation proceedings. Jul Aug. 2007;39(6):1918. Off topic. [pmid: 17692652].
818 Santos R, Pereira H. Economic evaluation of drug eluting stents in coronary angioplasty. Revista Portuguesa de Cardiologia. Nov. 2005;24(11):1409. Review. [pmid: 16463989].
819 Sarkar SD. Benign thyroid disease: what is the role of nuclear medicine?. Seminars in nuclear medicine. Jul. 2006;36(3):185. Off topic. [pmid: 16762609].
820 Schadlich PK, Schmidt-Lucke C, Huppertz E, et al. Economic evaluation of enoxaparin for anticoagulation in early cardioversion of persisting nonvalvular atrial fibrillation: a statutory health insurance perspective from Germany. American Journal of Cardiovascular Drugs. 2007;7(3):199. Cost Only. [pmid: 17610347].
821 Scharff RL, Jessup A. Evaluating chronic disease for heterogeneous populations: the case of arthritis. Medical care. Sep. 2007;45(9):860. Statistical Analysis. [pmid: 17712256].
822 Schermerhorn M. Should usual criteria for intervention in abdominal aortic aneurysms be “downsized,” considering reported risk reduction with endovascular repair?. Annals of the New York Academy of Sciences. Nov. 2006;1085:47. Off topic. [pmid: 17182922].
823 Scherrer B, Dojat M, Forbes F, et al. Agentification of Markov model-based segmentation: application to magnetic resonance brain scans. Artificial Intelligence in Medicine. May. 2009;46(1):81-95. Off topic. [pmid: 18929472].
824 Schimpf MO, Gottenger EE, Wagner JR. Universal ureteral stent placement at hysterectomy to identify ureteral injury: a decision analysis. BJOG: An International Journal of Obstetrics & Gynaecology. Aug. 2008;115(9):1151. Costs only. [pmid: 18518875].
825 Schlander M. Long acting medications for the hyperkinetic disorders. A note on cost effectiveness. European child & adolescent psychiatry. Oct. 2007;16(7):421. Off topic. [pmid: 17401606].
826 Schlander M. NICE accountability for reasonableness: a qualitative study of its appraisal of treatments for attention deficit/hyperactivity disorder (ADHD). Current Medical Research & Opinion. Jan. 2007;23(1):207. Off topic. [pmid: 17261237].
827 Schlander M. The use of cost effectiveness by the National Institute for Health and Clinical Excellence (NICE) no(t yet an) exemplar of a deliberative process. Journal of medical ethics. Jul. 2008;34(7):534. Off topic. [pmid: 18591289].
828 Schleinitz MD, DePalo D, Blume J, et al. Can differences in breast cancer utilities explain disparities in breast cancer care?. Journal of General Internal Medicine. Dec. 2006;21(12):1253. Off topic. [pmid: 16961753].
829 Schmidt WP, Genser B, Chalabi Z. A simulation model for diarrhoea and other common recurrent infections: a tool for exploring epidemiological methods. Epidemiology & Infection. May. 2009;137(5):644-53. Off topic. [pmid: 18840321].
830 Schmier JK, Jones ML, Halpern MT. The burden of age related macular degeneration. PharmacoEconomics. 2006;24(4):319. Review. [pmid: 16605279].
831 Schmittdiel J, Vijan S, Fireman B, et al. Predicted quality adjusted life years as a composite measure of the clinical value of diabetes risk factor control. Medical care. Apr. 2007;45(4):315. Statistical Analysis. [pmid: 17496715].
832 Schneider M, Norman R, Parry C, et al. Estimating the burden of disease attributable to alcohol use in South Africa in 2000. South African Medical Journal.Suid Afrikaanse Tydskrif Vir Geneeskunde. Aug. 2007;97(8 Pt 2):664. Off topic. [pmid: 17952223].
833 Schneider M, Norman R, Steyn N, et al. Estimating the burden of disease attributable to low fruit and vegetable intake in South Africa in 2000. South African Medical Journal.Suid Afrikaanse Tydskrif Vir Geneeskunde. Aug. 2007;97(8 Pt 2):717. Off topic. [pmid: 17952229].
834 Schoderbek RJ Jr., Brown TE, Mulhall KJ, et al. Extensor mechanism disruption after total knee arthroplasty. Clinical Orthopaedics & Related Research. May. 2006;446:176. Review. [pmid: 16672886].
835 Schousboe JT. Cost effectiveness modeling research of pharmacologic therapy to prevent osteoporosis related fractures. Current rheumatology reports. Apr. 2007;9(1):50. Off topic. [pmid: 17437668].
836 Schousboe JT. Cost effectiveness of screen and treat strategies for low bone mineral density: how do we screen, who do we screen and who do we treat?. Applied Health Economics & Health Policy. 2008;6(1):1. Review. [pmid: 18774866].
837 Schramm P, Huang Y, Erb G, et al. How does the injection protocol influence the attenuation-time curve in CT perfusion measurements: comparison of measured and simulated data. Medical Physics. Aug. 2009;36(8):3487-94. Off topic. [pmid: 19746782].
838 Schreinemakers JM, Elias SG, Borel Rinkes IH. Retroperitoneal endoscopic versus conventional open adrenalectomy: a cost effectiveness analysis. Journal of Laparoendoscopic & Advanced Surgical Techniques.Part A. Oct. 2008;18(5):707. Off topic. [pmid: 18803513].
839 Schwappach DL, Boluarte TA. HEE GER: a systematic review of German economic evaluations of health care published 1990 2004. BMC Health Services Research. 2007;7:7. Review. [pmid: 17222334].
840 Schwartz AM, Henson DE, American College of Chest P. Diagnostic surgical pathology in lung cancer: ACCP evidence based clinical practice guidelines (2nd edition). Chest. Sep. 2007;132(3 Suppl):78S. Off topic. [pmid: 17873162].
841 Scott J, Colom F, Popova E, et al. Long-term mental health resource utilization and cost of care following group psychoeducation or unstructured group support for bipolar disorders: a cost-benefit analysis. Journal of Clinical Psychiatry. Mar. 2009;70(3):378-86. Statistical analysis. [pmid: 19284929].
842 Scuffham PA, Whitty JA, Mitchell A, et al. The use of QALY weights for QALY calculations: a review of industry submissions requesting listing on the Australian Pharmaceutical Benefits Scheme 2002 4. PharmacoEconomics. 2008;26(4):297. Off topic. [pmid: 18370565].
843 Sculpher M. The use of quality adjusted life years in cost effectiveness studies. Allergy. May. 2006;61(5):527. Cost only. [pmid: 16629779].
844 Sculpher M. Subgroups and heterogeneity in cost effectiveness analysis. PharmacoEconomics. 2008;26(9):799. Off topic. [pmid: 18767899].
845 Sculpher MJ, Claxton K, Drummond M, et al. Whither trial based economic evaluation for health care decision making?. Health economics. Jul. 2006;15(7):677. Off topic. [pmid: 16491461].
846 Secin FP, Bianco FJ, Cronin A, et al. Is it necessary to remove the seminal vesicles completely at radical prostatectomy? decision curve analysis of European Society of Urologic Oncology criteria. Journal of Urology. discussion 614. Feb. 2009;181(2):609. Statistical Analysis. [pmid: 19084852].
847 Secker-Walker RH, Holland RR, Lloyd CM, et al. Cost effectiveness of a community based research project to help women quit smoking. Tobacco control. Feb. 2005;14(1):37. Statistical Analysis. [pmid: 15735298].
848 Sendi P. Bridging the gap between health and non health investments: moving from cost effectiveness analysis to a return on investment approach across sectors of economy. International Journal of Health Care Finance & Economics. Jun. 2008;8(2):113. Off topic. [pmid: 18351456].
849 Seror V. What understanding of decision making in prenatal screening could decision analysis provide?. Ultrasound in Obstetrics & Gynecology. Dec. 2007;30(7):921. Cost only. [pmid: 18044825].
850 Seror V. Fitting observed and theoretical choices women's choices about prenatal diagnosis of Down syndrome. Health economics. May. 2008;17(5):557. Off topic. [pmid: 17806133].
851 Seroussi B, Bouaud J, Gligorov J, et al. Supporting multidisciplinary staff meetings for guideline based breast cancer management: a study with OncoDoc2. AMIA . Annual Symposium Proceedings/AMIA Symposium. 2007:656-60. Off topic.
852 Severens JL, Brunenberg DE, Fenwick EA, et al. Cost effectiveness acceptability curves and a reluctance to lose. PharmacoEconomics. 2005;23(12):1207. Off topic. [pmid: 16336015].
853 Shah SP, Cheung KJ Jr., Johnson NA, et al. Model-based clustering of array CGH data. Bioinformatics. Jun. 15. 2009;25(12):i30-8. Off topic. [pmid: 19478003].
854 Shankaran V, McKoy JM, Dandade N, et al. Costs and cost effectiveness of a low intensity patient directed intervention to promote colorectal cancer screening. Journal of Clinical Oncology. Nov. 20. 2007;25(33):5248. Statistical Analysis. [pmid: 18024871].
855 Shapiro S. Does retention of the ovaries improve long term survival after hysterectomy? The validity of the epidemiological evidence. Climacteric. Jun. 2006;9(3):161. Review. [pmid: 16766428].
856 Shariat SF, Kattan MW, Vickers AJ, et al. Critical review of prostate cancer predictive tools. Future Oncology. Dec. 2009;5(10):1555-84. Review. [pmid: 20001796].
857 Sharieff W, Zlotkin S, Tondeur M, et al. Physiologic mechanisms can predict hematologic responses to iron supplements in growing children: a computer simulation model. American Journal of Clinical Nutrition. Mar. 2006;83(3):681. Off topic. [pmid: 16522917].
858 Shechter SM, Bryce CL, Alagoz O, et al. A clinically based discrete event simulation of end stage liver disease and the organ allocation process. Medical Decision Making. Mar-Apr. 2005;25(2):199. Off topic. [pmid: 15800304].
859 Sherman M. Hepatocellular carcinoma: epidemiology, risk factors, and screening. Seminars in liver disease. 2005;25(2):143. Off topic. [pmid: 15918143].
860 Shi H, Lyons-Weiler J. Clinical decision modeling system. BMC Medical Informatics & Decision Making. 2007;7:23. Off topic. [pmid: 17697328].
861 Shih YC, Han S, Cantor SB. Impact of generic drug entry on cost effectiveness analysis. Medical Decision Making. Jan-Feb. 2005;25(1):71. Off topic. [pmid: 15673583].
862 Shillcutt SD, Walker DG, Goodman CA, et al. Cost effectiveness in low- and middle-income countries: a review of the debates surrounding decision rules. Pharmacoeconomics. 2009;27(11):903-17. Review. [pmid: 19888791].
863 Shim E, Galvani AP. Impact of transmission dynamics on the cost-effectiveness of rotavirus vaccination. Vaccine. Jun. 19. 2009;27(30):4025. Off topic. [pmid: 19389452].
864 Shin SH, Hashimoto T, Hatano S. Automatic detection system for cough sounds as a symptom of abnormal health condition. IEEE Transactions on Information Technology in Biomedicine. Jul. 2009;13(4):486-93. Off topic. [pmid: 19273017].
865 Shires JD, de Jong GC. An international meta-analysis of values of travel time savings. Evaluation & Program Planning. Nov. 2009;32(4):315-25. Off topic. [pmid: 19679355].
866 Shrive FM, Ghali WA, Johnson JA, et al. Use of the U.S. and U.K. scoring algorithm for the EuroQol 5D in an economic evaluation of cardiac care. Medical care. Mar. 2007;45(3):269. Off topic. [pmid: 17304086].
867 Shu Y, Klein JP, Zhang MJ. Asymptotic theory for the Cox semi Markov illness death model. Lifetime Data Analysis. Mar. 2007;13(1):91. Off topic. [pmid: 17115258].
868 Siegel JE, Clancy CM. Relative value in healthcare: cost effectiveness of interventions. Journal of nursing care quality. Apr-Jun. 2006;21(2):99. Cost only. [pmid: 16540774].
869 Simoens S, Laekeman G. Pharmacotherapy of allergic rhinitis: a pharmaco-economic approach. Allergy. Jan. 2009;64(1):85-95. Review. [pmid: 19076532].
870 Simoens S, Ophals E, Schuermans A. Search and destroy policy for methicillin-resistant Staphylococcus aureus: cost-benefit analysis. Journal of Advanced Nursing. Sep. 2009;65(9):1853-9. Off topic. [pmid: 19694848].
871 Simon J, Petrou S, Gray A. The valuation of prenatal life in economic evaluations of perinatal interventions. Health economics. Apr. 2009;18(4):487. Off topic. [pmid: 18615854].
872 Sims TL, Garber AM, Miller DE, et al. Multimedia quality of life assessment: advances with FLAIR. AMIA Annual Symposium Proceedings. 2005:694-8. Off topic. [pmid: 16779129].
873 Singh NP, Ingle GK, Saini VK, et al. Prevalence of low glomerular filtration rate, proteinuria and associated risk factors in North India using Cockcroft-Gault and Modification of Diet in Renal Disease equation: an observational, cross-sectional study. BMC Nephrology. 2009;10:4. Statistical analysis. [pmid: 19220921].
874 Sistino J. Using decision analysis and meta analysis to predict coronary artery bypass surgical outcomes a model for comparing off pump surgery to miniaturized cardiopulmonary bypass circuits. Perfusion. Sep. 2008;23(5):255. Statistical analysis. [pmid: 19346262].
875 Sistrom CL. The appropriateness of imaging: a comprehensive conceptual framework. Radiology. Jun. 2009;251(3):637. Off topic. [pmid: 19474372].
876 Skidmore ER, Rogers JC, Chandler LS, et al. Dynamic interactions between impairment and activity after stroke: examining the utility of decision analysis methods. Clinical rehabilitation. Jun. 2006;20(6):523. Statistical Analysis. [pmid: 16892934].
877 Skidmore ER, Rogers JC, Chandler LS, et al. Developing empirical models to enhance stroke rehabilitation. Disability & Rehabilitation. Aug. 30. 2006;28(16):1027. Review. [pmid: 16882642].
878 Skidmore ER, Rogers JC, Chandler LS, et al. A precise method for linking neuroanatomy to function after stroke: a pilot study. Topics in Stroke Rehabilitation. Sep Oct. 2007;14(5):12. Off topic. [pmid: 17901011].
879 Slomka J, Quill B, des Vignes-Kendrick M, et al. Professionalism and ethics in the public health curriculum. Public health reports. 2008;123(Suppl 2):27. Off topic. [pmid: 18770917].
880 Smith CA, Frick KD. Cost utility analysis of high vs. low intensity home and community based service interventions. Social Work in Public Health. 2008;23(6):75. Off topic. [pmid: 19301545].
881 Smith K, Ba SO, Odobez JM, et al. Tracking the visual focus of attention for a varying number of wandering people. IEEE Transactions on Pattern Analysis & Machine Intelligence. Jul. 2008;30(7):1212. Off topic. [pmid: 18550904].
882 Smith KJ, Barnato AE, Roberts MS. Teaching medical decision modeling: a qualitative description of student errors and curriculum responses. Medical Decision Making. Nov-Dec. 2006;26(6):583. Off topic. [pmid: 17099196].
883 Smith MV, Boyd WA, Kissling GE, et al. A discrete time model for the analysis of medium-throughput C. elegans growth data. PLoS ONE [Electronic Resource]. 2009;4(9):e7018. Off topic.
884 Smith SW, Portelli I, Narzisi G, et al. A novel approach to multihazard modeling and simulation. Disaster Medicine & Public Health Preparedness. Jun. 2009;3(2):75-87. Off topic. [pmid: 19491602].
885 Smith WP, Doctor J, Meyer J, et al. A decision aid for intensity-modulated radiation-therapy plan selection in prostate cancer based on a prognostic Bayesian network and a Markov model. Artificial Intelligence in Medicine. Jun. 2009;46(2):119. Decision aid. [pmid: 19157811].
886 Smolen HJ, Cohen DJ, Samsa GP, et al. Development, validation, and application of a microsimulation model to predict stroke and mortality in medically managed asymptomatic patients with significant carotid artery stenosis. Value in Health. Nov Dec. 2007;10(6):489. Off topic. [pmid: 17970931].
887 Smolkin MT. Medicare and cost effectiveness analysis. New England Journal of Medicine. author reply 207-9. Jan. 12. 2006;354(2):207. Cost only. [pmid: 16411303].
888 Snik AF, van Duijnhoven NT, Mylanus EA, et al. Estimated cost effectiveness of active middle ear implantation in hearing impaired patients with severe external otitis. Archives of Otolaryngology Head & Neck Surgery. Nov. 2006;132(11):1210. Statistical Analysis. [pmid: 17116816].
889 Snir S, Tuller T. The NET-HMM approach: phylogenetic network inference by combining maximum likelihood and Hidden Markov Models. Journal of Bioinformatics & Computational Biology. Aug. 2009;7(4):625-44. Off topic. [pmid: 19634195].
890 Sobocki P, Ekman M, Agren H, et al. Health related quality of life measured with EQ 5D in patients treated for depression in primary care. Value in Health. Mar Apr. 2007;10(2):153. Statistical Analysis. [pmid: 17391424].
891 Sobocki P, Jonsson B, Angst J, et al. Cost of depression in Europe. The Journal of Mental Health Policy & Economics. Jun. 2006;9(2):87. Off topic. [pmid: 17007486].
892 Soegaard R, Christensen FB, Christiansen T, et al. Costs and effects in lumbar spinal fusion. A follow up study in 136 consecutive patients with chronic low back pain. European Spine Journal. May. 2007;16(5):657. Statistical Analysis. [pmid: 16871387].
893 Solheim BG. Universal pathogen reduced plasma in elective open heart surgery and liver resection. Clinical Medicine & Research. Sep. 2006;4(3):209. Review. [pmid: 16988101].
894 Solomkin JS. Cost effectiveness issues in ventilator associated pneumonia. Respiratory care. discussion 963-4. Jul. 2005;50(7):956. Off topic. [pmid: 15972115].
895 Sommen C, Alioum A, Commenges D. A multistate approach for estimating the incidence of human immunodeficiency virus by using HIV and AIDS French surveillance data. Statistics in Medicine. May. 15. 2009;28(11):1554-68. Off topic. [pmid: 19278012].
896 Sone Y, Kumada T, Toyoda H, et al. Eradicating Helicobacter pylori in peptic ulcer disease reduces medical costs in the community. Helicobacter. Oct. 2008;13(5):346. Off topic. [pmid: 19250509].
897 Sonnenberg A. Personal view: passing the buck and taking a free ride a game theoretical approach to evasive management strategies in gastroenterology. Alimentary Pharmacology & Therapeutics. Sep. 15. 2005;22(6):513. Off topic. [pmid: 16167967].
898 Sparrow JM. Monte Carlo simulation of random clustering of endophthalmitis following cataract surgery. Eye. Feb. 2007;21(2):209. Off topic. [pmid: 16311528].
899 Spatz AL, Zakrzewska JM, Kay EJ. Decision analysis of medical and surgical treatments for trigeminal neuralgia: how patient evaluations of benefits and risks affect the utility of treatment decisions. Pain. Oct. 2007;131(3):302. Statistical Analysis. [pmid: 17451880].
900 Spiegel DA, Gosselin RA, Coughlin RR, et al. Topics in global public health. Clinical Orthopaedics & Related Research. Oct. 2008;466(10):2377. Off topic. [pmid: 18712457].
901 Sporer SM, Rosenberg AG. Decision analysis in orthopaedics. Clinical Orthopaedics & Related Research. Feb. 2005;(431):250. Off topic. [pmid: 15685085].
902 Stahl JE, Sandberg WS, Daily B, et al. Reorganizing patient care and workflow in the operating room: a cost effectiveness study. Surgery. Jun. 2006;139(6):717. Statistical Analysis. [pmid: 16782425].
903 Stamatakos GS, Antipas VP, Uzunoglu NK. Simulating chemotherapeutic schemes in the individualized treatment context: the paradigm of glioblastoma multiforme treated by temozolomide in vivo. Computers in Biology & Medicine. Nov. 2006;36(11):1216. Off topic. [pmid: 16207487].
904 Stamatakos GS, Antipas VP, Uzunoglu NK. A spatiotemporal, patient individualized simulation model of solid tumor response to chemotherapy in vivo: the paradigm of glioblastoma multiforme treated by temozolomide. IEEE Transactions on Biomedical Engineering. Aug. 2006;53(8):1467. Off topic. [pmid: 16916081].
905 Starkey SR, White ME, Mohammed HO. Cryptosporidium and dairy cattle in the Catskill/Delaware watershed: a quantitative risk assessment. Risk Analysis. Dec. 2007;27(6):1469. Off topic. [pmid: 18093047].
906 Starkie HJ, Briggs AH, Chambers MG. Pharmacoeconomics in COPD: lessons for the future. International Journal of Copd. 2008;3(1):71. Off topic. [pmid: 18488430].
907 Stein AJ, Meenakshi JV, Qaim M, et al. Potential impacts of iron biofortification in India. Social science & medicine. Apr. 2008;66(8):1797. Off topic. [pmid: 18291567].
908 Stein AJ, Nestel P, Meenakshi JV, et al. Plant breeding to control zinc deficiency in India: how cost effective is biofortification?. Public health nutrition. May. 2007;10(5):492. Statistical Analysis. [pmid: 17411470].
909 Stein SC, Hurst RW, Sonnad SS. Meta analysis of cranial CT scans in children. A mathematical model to predict radiation induced tumors. Pediatric neurosurgery. 2008;44(6):448. Off topic. [pmid: 19018153].
910 Steuten LM, Vrijhoef HJ, Landewe-Cleuren S, et al. A disease management programme for patients with diabetes mellitus is associated with improved quality of care within existing budgets. Diabetic Medicine. Oct. 2007;24(10):1112. Statistical Analysis. [pmid: 17672862].
911 Stevens KJ, Brazier JE, McKenna SP, et al. The development of a preference based measure of health in children with atopic dermatitis. British Journal of Dermatology. Aug. 2005;153(2):372. Off topic. [pmid: 16086752].
912 Stevenson JC, Mahoney ER, Walker PL, et al. Technical note: prediction of sex based on five skull traits using decision analysis (CHAID). American Journal of Physical Anthropology. Jul. 2009;139(3):434. Off topic. [pmid: 19350636].
913 Stevenson LW, Stevenson WG. Cost effectiveness of ICDs. New England Journal of Medicine. author reply 205-7. Jan. 12. 2006;354(2):205. Cost only. [pmid: 16411295].
914 Stevenson M, Yu J, Hendrie D, et al. Reducing the burden of road traffic injury: translating high income country interventions to middle income and low income countries. Injury Prevention. Oct. 2008;14(5):284. Off topic. [pmid: 18836043].
915 Stiggelbout AM, de Vogel-Voogt E. Health state utilities: a framework for studying the gap between the imagined and the real. Value in Health. Jan Feb. 2008;11(1):76. Off topic. [pmid: 18237362].
916 Stone PW, Schackman BR, Neukermans CP, et al. A synthesis of cost utility analysis literature in infectious disease. The Lancet Infectious Diseases. Jun. 2005;5(6):383. Review. [pmid: 15919624].
917 Stout NK, Goldie SJ. Keeping the noise down: common random numbers for disease simulation modeling. Health care management science. Dec. 2008;11(4):399. Off topic. [pmid: 18998599].
918 Strachan IGD, Hughes NP, Poonawala MH, et al. Automated QT analysis that learns from cardiologist annotations. Annals of Noninvasive Electrocardiology. Jan. Suppl 1. 2009;14:S9-21. Off topic. [pmid: 19143745].
919 Straube R, Ridgway D. Investigating the effects of molecular crowding on Ca2+ diffusion using a particle-based simulation model. Chaos. Sep. 2009;19(3):037110. Off topic. [pmid: 19792035].
920 Suaya JA, Shepard DS, Chang MS, et al. Cost effectiveness of annual targeted larviciding campaigns in Cambodia against the dengue vector Aedes aegypti. Tropical Medicine & International Health. Sep. 2007;12(9):1026. Statistical Analysis. [pmid: 17875014].
921 Sucov A, Sidman R, Valente J. A cost-efficiency analysis to increase clinician staffing in an academic emergency department. Academic Medicine. Sep. 2009;84(9):1211. Off topic. [pmid: 19707059].
922 Sullivan PW, Ghushchyan V. Preference Based EQ 5D index scores for chronic conditions in the United States. Medical Decision Making. Jul-Aug. 2006;26(4):410. Off topic. [pmid: 16855129].
923 Sullivan PW, Lawrence WF, Ghushchyan V. A national catalog of preference based scores for chronic conditions in the United States. Medical care. Jul. 2005;43(7):736. Off topic. [pmid: 15970790].
924 Sun S, Greenwood CM, Neal RM. Haplotype inference using a Bayesian Hidden Markov model. Genetic epidemiology. Dec. 2007;31(8):937. Off topic. [pmid: 17630649].
925 Sun W, Xie W, Xu F, et al. Dissecting nucleosome free regions by a segmental semi-Markov model. PLoS ONE [Electronic Resource]. 2009;4(3):e4721. Off topic.
926 Sun X, Faunce T. Decision analytical modelling in health care economic evaluations. European Journal of Health Economics. Nov. 2008;9(4):313. Off topic. [pmid: 17943332].
927 Sun X, Qin WX, Li YP, et al. Comparative cost effectiveness of antiviral therapies in patients with chronic hepatitis B: a systematic review of economic evidence. Journal of Gastroenterology & Hepatology. Sep. 2007;22(9):1369. Review. [pmid: 17716343].
928 Sundaramoorthi D, Chen VCP, Rosenberger JM, et al. A data-integrated simulation model to evaluate nurse-patient assignments. Health Care Management Science. Sep. 2009;12(3):252-68. Off topic. [pmid: 19739359].
929 Stratton RJ, Elia M, British Artificial Nutrition (BAN) Survey. A cost utility analysis in patients receiving enteral tube feeding at home and in nursing homes. Proceedings of the Nutrition Society. May. 2008;67(OCE):E111. No abstract. [pmid: 18598439].
930 Sutton AJ, Cooper NJ, Goodacre S, et al. Integration of meta analysis and economic decision modeling for evaluating diagnostic tests. Medical Decision Making. Sep Oct. 2008;28(5):650. Off topic. [pmid: 18753686].
931 Sutton AJ, Cooper NJ, Jones DR, et al. Evidence based sample size calculations based upon updated meta analysis. Statistics in medicine. May. 30. 2007;26(12):2479. Off topic. [pmid: 16981184].
932 Suwa M, Ono Y. Computational overview of GPCR gene universe to support reverse chemical genomics study. Methods in Molecular Biology. 2009;577:41-54. Off topic. [pmid: 19718507].
933 Swillens A, Lovstakken L, Kips J, et al. Ultrasound simulation of complex flow velocity fields based on computational fluid dynamics. IEEE Transactions on Ultrasonics Ferroelectrics & Frequency Control. Mar. 2009;56(3):546-56. Off topic.
934 Szucs TD, Bramkamp M. Pharmacoeconomics of anticoagulation therapy for stroke prevention in atrial fibrillation: a review. Journal of Thrombosis & Haemostasis. Jun. 2006;4(6):1180. Review. [pmid: 16706956].
935 Takach TJ, Reul GJ, Duncan JM, et al. Concomitant brachiocephalic and coronary artery disease: outcome and decision analysis. Annals of Thoracic Surgery. Aug. 2005;80(2):564. Statistical Analysis. [pmid: 16039206].
936 Talmor D, Greenberg D, Howell MD, et al. The costs and cost effectiveness of an integrated sepsis treatment protocol. Critical care medicine. Apr. 2008;36(4):1168. Off topic. [pmid: 18379243].
937 Talmor D, Shapiro N, Greenberg D, et al. When is critical care medicine cost effective? A systematic review of the cost effectiveness literature. Critical care medicine. Nov. 2006;34(11):2738. Review. [pmid: 16957636].
938 Talwalkar JA. Cost effectiveness of treating esophageal varices. Clinics in liver disease. Aug. 2006;10(3):xi. 679. Review.
939 Tam VH, Adams S, LaRocco MT, et al. An integrated pharmacoeconomic approach to antimicrobial formulary decision making. American Journal of Health System Pharmacy. Apr. 15. 2006;63(8):735. Off topic. [pmid: 16595813].
940 Tamaki Y, Nomura Y, Katsumura S, et al. Construction of a dental caries prediction model by data mining. Journal of oral science. Mar. 2009;51(1):61. Off topic. [pmid: 19325201].
941 Tang H, Mayersohn M. Accuracy of allometrically predicted pharmacokinetic parameters in humans: role of species selection. Drug Metabolism & Disposition. Sep. 2005;33(9):1288. Off topic. [pmid: 15919852].
942 Tang J, Wang X. Analysis of the land use structure changes based on Lorenz curves. Environmental Monitoring & Assessment. Apr. 2009;151(1-4):175-80. Off topic. [pmid: 18386147].
943 Tappenden P, Brazier J, Ratcliffe J, et al. A stated preference binary choice experiment to explore NICE decision making. PharmacoEconomics. 2007;25(8):685. Off topic. [pmid: 17640110].
944 Tappenden P, Chilcott J, Ward S, et al. Methodological issues in the economic analysis of cancer treatments. European journal of cancer. Nov. 2006;42(17):2867. Off topic. [pmid: 17023160].
945 Taroni F, Bozza S, Aitken C. Decision analysis in forensic science. Journal of forensic sciences. Jul. 2005;50(4):894. Off topic. [pmid: 16078494].
946 Taroni F, Bozza S, Bernard M, et al. Value of DNA tests: a decision perspective. Journal of forensic sciences. Jan. 2007;52(1):31. Off topic. [pmid: 17209907].
947 Tatsch FF, Sette H Jr., Vianna D. Pharmacoeconomics applied to chronic hepatitis C. Brazilian Journal of Infectious Diseases. Feb. 2006;10(1):51. Off topic. [pmid: 16767316].
948 Taylor AJ, Bindeman J, Feuerstein I, et al. Coronary calcium independently predicts incident premature coronary heart disease over measured cardiovascular risk factors: mean three year outcomes in the Prospective Army Coronary Calcium (PACC) project. Journal of the American College of Cardiology. Sep. 6. 2005;46(5):807. Statistical Analysis. [pmid: 16139129].
949 Taylor PS, Faeth I, Marks MK, et al. Cost of treating otitis media in Australia. Expert Review of Pharmacoeconomics & Outcomes Research. Apr. 2009;9(2):133. Cost Only. [pmid: 19402800].
950 Taylor RS, Elston J. The use of surrogate outcomes in model-based cost-effectiveness analyses: a survey of UK Health Technology Assessment reports. Health technology assessment (Winchester, England). 1. 50. Jan. 2009;13(8):ix-xi. iii. ix. Off topic.
951 Taylor RS, Van Buyten JP, Buchser E. Spinal cord stimulation for complex regional pain syndrome: a systematic review of the clinical and cost effectiveness literature and assessment of prognostic factors. European Journal of Pain: Ejp. Feb. 2006;10(2):91. Statistical Analysis.
952 Taylor RS, Watt A, Dalal HM, et al. Home based cardiac rehabilitation versus hospital based rehabilitation: a cost effectiveness analysis. International journal of cardiology. Jul. 10. 2007;119(2):196. Statistical Analysis. [pmid: 17084927].
953 Techakehakij W, Feldman RD. Cost effectiveness of HPV vaccination compared with Pap smear screening on a national scale: a literature review. Vaccine. Nov. 18. 2008;26(49):6258. Review. [pmid: 18835313].
954 Temple R. Quantitative decision analysis: a work in progress. Clinical Pharmacology & Therapeutics. Aug. 2007;82(2):127. Off topic. [pmid: 17632535].
955 Tewari M. Contribution of silent gallstones in gallbladder cancer. Journal of surgical oncology. Jun. 15. 2006;93(8):629. Off topic. [pmid: 16724346].
956 Thiel JA, Carson GD. Cost effectiveness analysis comparing the essure tubal sterilization procedure and laparoscopic tubal sterilization. Journal of Obstetrics & Gynaecology Canada: JOGC. Jul. 2008;30(7):581. Off topic.
957 Thiel R, Stroetmann KA, Stroetmann VN, et al. Designing a socio-economic assessment method for integrative biomedical research: the Osteoporotic Virtual Physiological Human project. Studies in Health Technology & Informatics. 2009;150:876-80. Review. [pmid: 19745438].
958 Thompson KM, Duintjer Tebbens RJ, Pallansch MA, et al. Development and consideration of global policies for managing the future risks of poliovirus outbreaks: insights and lessons learned through modeling. Risk Analysis. Dec. 2006;26(6):1571. Review. [pmid: 17184398].
959 Thompson S, Kim L, Gao L. Abdominal aortic aneurysm Comparing studies for cost effectiveness of screening. Bmj. 2009;339:b3044. Other. [pmid: 19638382].
960 Thomson P, Dowding D, Swanson V, et al. A computerised guidance tree (decision aid) for hypertension, based on decision analysis: development and preliminary evaluation. European Journal of Cardiovascular Nursing. Jun. 2006;5(2):146. Review. [pmid: 16309966].
961 Thomson R, Eccles M, Wood R, et al. A cautionary note on data sources for evidence based clinical decisions: warfarin and stroke prevention. Medical Decision Making. Jul Aug. 2007;27(4):438. Off topic. [pmid: 17641140].
962 Thornton J, Elliott RA, Tully MP, et al. Clinical and economic choices in the treatment of respiratory infections in cystic fibrosis: comparing hospital and home care. Journal of Cystic Fibrosis. Dec. 2005;4(4):239. Statistical Analysis. [pmid: 16242385].
963 Tilford JM, Aitken ME, Goodman AC, et al. Measuring the cost effectiveness of technologic change in the treatment of pediatric traumatic brain injury. Journal of Trauma Injury Infection & Critical Care. discussion S121. Dec. 2007;63(6 Suppl):S113. Statistical Analysis.
964 Tilford JM, Aitken ME, Goodman AC, et al. Child health related quality of life following neurocritical care for traumatic brain injury: an analysis of preference weighted outcomes. Neurocritical Care. 2007;7(1):64. Off topic. [pmid: 17657658].
965 Tilford JM, Grosse SD, Robbins JM, et al. Health state preference scores of children with spina bifida and their caregivers. Quality of Life Research. May. 2005;14(4):1087. Off topic. [pmid: 16041904].
966 Tillin T, Chambers M, Feldman R. Outcomes of electrically stimulated gracilis neosphincter surgery. Health technology assessment (Winchester, England). 1. 102. Jul. 2005;9(28):ix-xi. iii. ix. Off topic.
967 Tita AT, Grobman WA, Rouse DJ. Antenatal herpes serologic screening: an appraisal of the evidence. Obstetrics & Gynecology. Nov. 2006;108(5):1247. Off topic. [pmid: 17077252].
968 Titt U, Sahoo N, Ding X, et al. Assessment of the accuracy of an MCNPX based Monte Carlo simulation model for predicting three dimensional absorbed dose distributions. Physics in Medicine & Biology. Aug. 21. 2008;53(16):4455. Review. [pmid: 18670050].
969 Tompa E, Dolinschi R, Laing A. An economic evaluation of a participatory ergonomics process in an auto parts manufacturer. Journal of Safety Research. 2009;40(1):41-7. Statistical analysis. [pmid: 19285585].
970 Torgerson DJ. Cost-effectiveness analysis and health policy. Nestle Nutrition Workshop Series Clinical & Performance Program. 2009;12:95-104. Off topic.
971 Torgerson PR, Schweiger A, Deplazes P, et al. Alveolar echinococcosis: from a deadly disease to a well controlled infection. Relative survival and economic analysis in Switzerland over the last 35 years. Journal of hepatology. Jul. 2008;49(1):72. Off topic. [pmid: 18485517].
972 Torrance GW. Utility measurement in healthcare: the things I never got to. PharmacoEconomics. 2006;24(11):1069. Off topic. [pmid: 17067192].
973 Tournoud M, Etard JF, Ecochard R, et al. Adherence to antiretroviral therapy, virological response, and time to resistance in the Dakar cohort. Statistics in Medicine. Jan. 15. 2010;29(1):14-32. Off topic. [pmid: 19941299].
974 Toye F, Barlow J, Wright C, et al. A validation study of the New Zealand score for hip and knee surgery. Clinical Orthopaedics & Related Research. Nov. 2007;464:190. Off topic. [pmid: 18062051].
975 Trogdon J, Finkelstein EA, Reyes M, et al. A return-on-investment simulation model of workplace obesity interventions. Journal of Occupational & Environmental Medicine. Jul. 2009;51(7):751-8. Costs only. [pmid: 19528833].
976 Tseng MC, Lin HJ. Health related quality of life after stroke: review of the literature and implications for future research. Acta Neurologica Taiwanica. Mar. 2007;16(1):7. Off topic. [pmid: 17486727].
977 Tucker DM, Palmer AJ, Valentine WJ, et al. Counting the costs of overweight and obesity: modeling clinical and cost outcomes. Current Medical Research & Opinion. Mar. 2006;22(3):575. Off topic. [pmid: 16574040].
978 Tupasi TE, Gupta R, Quelapio MI, et al. Feasibility and cost effectiveness of treating multidrug resistant tuberculosis: a cohort study in the Philippines. PLoS Medicine / Public Library of Science. Sep. 2006;3(9):e352. Statistical Analysis.
979 Tuulonen A, Azuara-Blanco A. Cost-effectiveness. Ophthalmology. author reply 167. Jan. 2009;116(1):166. Other. [pmid: 19118707].
980 Ueda K, Hirano Y, Higashiuesato Y, et al. Role of HCN4 channel in preventing ventricular arrhythmia. Journal of Human Genetics. Feb. 2009;54(2):115-21. Off topic. [pmid: 19165230].
981 Unal B, Capewell S, Critchley JA. Coronary heart disease policy models: a systematic review. BMC Public Health. 2006;6:213. Review. [pmid: 16919155].
982 Unnanuntana A, Dimitroulias A, Bolognesi MP, et al. Cementless femoral prostheses cost more to implant than cemented femoral prostheses. Clinical Orthopaedics & Related Research. Jun. 2009;467(6):1546. Cost Only. [pmid: 18781368].
983 Urdahl H, Manca A, Sculpher MJ. Assessing generalisability in model based economic evaluation studies: a structured review in osteoporosis. PharmacoEconomics. 2006;24(12):1181. Review. [pmid: 17129074].
984 Urso P, Lualdi M, Colombo A, et al. Skin and cutaneous melanocytic lesion simulation in biomedical optics with multilayered phantoms. Physics in Medicine & Biology. May. 21. 2007;52(10):N229. Off topic. [pmid: 17473339].
985 Uyl-de Groot CA, Giaccone G. Health economics: can we afford an unrestricted use of new biological agents in gastrointestinal oncology?. Current opinion in oncology. Jul. 2005;17(4):392. Review. [pmid: 15933476].
986 Uyl-de Groot CA, Stupp R, van der Bent M. Cost-effectiveness of temozolomide for the treatment of newly diagnosed glioblastoma multiforme. Expert Review of Pharmacoeconomics & Outcomes Research. Jun. 2009;9(3):235. Review. [pmid: 19527095].
987 Uys PW, van Helden PD, Hargrove JW. Tuberculosis reinfection rate as a proportion of total infection rate correlates with the logarithm of the incidence rate: a mathematical model. Journal of the Royal Society Interface. Jan. 6. 2009;6(30):11-5. Off topic.
988 Vadali M, Ramachandran G, Mulhausen J. Exposure modeling in occupational hygiene decision making. Journal of Occupational & Environmental Hygiene. Jun. 2009;6(6):353-62. Off topic. [pmid: 19326267].
989 Valldeoriola F, Morsi O, Tolosa E, et al. Prospective comparative study on cost effectiveness of subthalamic stimulation and best medical treatment in advanced Parkinson's disease. Movement Disorders. Nov. 15. 2007;22(15):2183. Statistical Analysis. [pmid: 17724747].
990 van Baal PH, Feenstra TL, Hoogenveen RT, et al. Unrelated medical care in life years gained and the cost utility of primary prevention: in search of a ‘perfect’ cost utility ratio. Health economics. Apr. 2007;16(4):421. Off topic. [pmid: 17039573].
991 van den Broek FJ, de Graaf EJ, Dijkgraaf MG, et al. Transanal endoscopic microsurgery versus endoscopic mucosal resection for large rectal adenomas (TREND-study). BMC Surgery. 2009;9:4. Statistical Analysis. [pmid: 19284647].
992 van den Hout A, Matthews FE. Estimating dementia-free life expectancy for Parkinson's patients using Bayesian inference and microsimulation. Biostatistics. Oct. 2009;10(4):729-43. Off topic. [pmid: 19648228].
993 van den Hout A, Matthews FE. A piecewise-constant Markov model and the effects of study design on the estimation of life expectancies in health and ill health. Statistical Methods in Medical Research. Apr. 2009;18(2):145-62. Off topic. [pmid: 18445698].
994 van den Hout WB. Deficiencies in current evaluations of the cost-effectiveness of biologic agents for RA. Nature Clinical Practice Rheumatology. Feb. 2009;5(2):78. Other.
995 van den Hout WB, Kramer GW, Noordijk EM, et al. Cost utility analysis of short versus long course palliative radiotherapy in patients with non small cell lung cancer. Journal of the National Cancer Institute. Dec. 20. 2006;98(24):1786. Statistical Analysis. [pmid: 17179480].
996 van der Pol M, Roux L. Time preference bias in time trade off. European Journal of Health Economics. Jun. 2005;6(2):107. Off topic. [pmid: 19787847].
997 Van Hemel NM. A review of factors contributing to health related quality of life achieved with cardiac resynchronization therapy for heart failure. Minerva cardioangiologica. Dec. 2007;55(6):783. Review. [pmid: 18091646].
998 Van Howe RS. Effect of confounding in the association between circumcision status and urinary tract infection. Journal of Infection. Jul. 2005;51(1):59. Off topic. [pmid: 15979493].
999 van Hulst M, Bilgin YM, van de Watering LM, et al. Cost effectiveness of leucocyte depleted erythrocyte transfusion in cardiac valve surgery. Transfusion Medicine. Jun. 2005;15(3):209. Statistical Analysis. [pmid: 15943705].
1000 van Osch SM, Stiggelbout AM. The construction of standard gamble utilities. Health economics. Jan. 2008;17(1):31. Off topic. [pmid: 17410521].
1001 van Vliet EP, Steyerberg EW, Eijkemans MJ, et al. Detection of distant metastases in patients with oesophageal or gastric cardia cancer: a diagnostic decision analysis. British journal of cancer. Oct. 8. 2007;97(7):868. Statistical Analysis. [pmid: 17848957].
1002 Vasiliadis HM, Collet JP, Penrod JR, et al. A cost effectiveness and cost utility study of lung transplantation. Journal of Heart & Lung Transplantation. Sep. 2005;24(9):1275. Statistical Analysis. [pmid: 16143245].
1003 Vega JC, Sanchez BF, Montero LM, et al. Short communication: The cost effectiveness of cutaneous leishmaniasis patient management during an epidemic in Chaparral, Colombia in 2004. Tropical Medicine & International Health. Dec. 2007;12(12):1540. Statistical Analysis. [pmid: 18076562].
1004 Veldt BJ, Hansen BE, Eijkemans MJ, et al. Dynamic decision analysis to determine optimal treatment duration in chronic hepatitis C. Alimentary Pharmacology & Therapeutics. Mar. 1. 2005;21(5):539. Statistical Analysis. [pmid: 15740537].
1005 Veleva Z, Karinen P, Tomas C, et al. Elective single embryo transfer with cryopreservation improves the outcome and diminishes the costs of IVF/ICSI. Human Reproduction. Jul. 2009;24(7):1632. Statistical Analysis. [pmid: 19318704].
1006 Verheijde JL, Rady MY, McGregor JL. Hypothetical modeling about the cost effectiveness of kidney transplantation for end stage renal disease: untested assumptions, unaccounted variables and unknown consequences. Health Policy. Dec. 2008;88(2 3):392. No abstract. [pmid: 18486267].
1007 Verkaik-Kloosterman J, van 't Veer P, Ocke MC. Simulation model accurately estimates total dietary iodine intake. Journal of Nutrition. Jul. 2009;139(7):1419-25. Off topic. [pmid: 19474152].
1008 Verta M, Kiviranta H, Salo S, et al. A decision framework for possible remediation of contaminated sediments in the River Kymijoki, Finland. Environmental Science & Pollution Research. Jan. 2009;16(1):95-105. Off topic. [pmid: 18941816].
1009 Vetter TR. A primer on health related quality of life in chronic pain medicine. Anesthesia & Analgesia. Mar. 2007;104(3):703. Off topic. [pmid: 17312232].
1010 Vijgen SM, van Baal PH, Hoogenveen RT, et al. Cost effectiveness analyses of health promotion programs: a case study of smoking prevention and cessation among Dutch students. Health education research. Apr. 2008;23(2):310. Off topic. [pmid: 17675649].
1011 Virkki LM, Konttinen YT, Peltomaa R, et al. Cost effectiveness of infliximab in the treatment of rheumatoid arthritis in clinical practice. Clinical & Experimental Rheumatology. Nov Dec. 2008;26(6):1059. Off topic. [pmid: 19210870].
1012 Vitale MA, Vitale MG, Zivin JG, et al. Rotator cuff repair: an analysis of utility scores and cost effectiveness. Journal of Shoulder & Elbow Surgery. Mar Apr. 2007;16(2):181. Statistical Analysis. [pmid: 17399623].
1013 Von Kohorn I, Ehrenkranz RA. Anemia in the preterm infant: erythropoietin versus erythrocyte transfusion--it's not that simple. Clinics in Perinatology. Mar. 2009;36(1):111-23. Off topic. [pmid: 19161869].
1014 Vonkeman HE, Braakman-Jansen LM, Klok RM, et al. Incremental cost effectiveness of proton pump inhibitors for the prevention of non steroidal anti inflammatory drug ulcers: a pharmacoeconomic analysis linked to a case control study. Arthritis Research & Therapy. 2008;10(6):R144. Statistical analysis. [pmid: 19077318].
1015 Walker S, Palmer S, Erhorn S, et al. Fludarabine phosphate for the first-line treatment of chronic lymphocytic leukaemia. Health technology assessment (Winchester, England). Jun. 2009;13(Suppl 1):35. Review.
1016 Wall MM, Li R. Multiple indicator hidden Markov model with an application to medical utilization data. Statistics in Medicine. Jan. 30. 2009;28(2):293-310. Off topic. [pmid: 18991318].
1017 Walters D, Connor JP, Feeney GF, et al. The cost effectiveness of naltrexone added to cognitive-behavioral therapy in the treatment of alcohol dependence. Journal of Addictive Diseases. 2009;28(2):137. Off topic. [pmid: 19340676].
1018 Wang H, Veldink JH, Blauw H, et al. Markov Models for inferring copy number variations from genotype data on Illumina platforms. Human Heredity. 2009;68(1):1-22. Costs only. [pmid: 19339782].
1019 Wang H, Zhao H. Estimating incremental cost effectiveness ratios and their confidence intervals with differentially censored data. Biometrics. Jun. 2006;62(2):570. Off topic. [pmid: 16918922].
1020 Wang H, Zhao H. A study on confidence intervals for incremental cost effectiveness ratios. Biometrical Journal. Aug. 2008;50(4):505. Off topic. [pmid: 18663759].
1021 Wang J, Keightley PD, Johnson T. MCALIGN2: faster, accurate global pairwise alignment of non coding DNA sequences based on explicit models of indel evolution. BMC Bioinformatics. 2006;7:292. Off topic. [pmid: 16762073].
1022 Ward S, Pilgrim H, Hind D. Trastuzumab for the treatment of primary breast cancer in HER2-positive women: a single technology appraisal. Health technology assessment (Winchester, England). Jun. 2009;13(Suppl 1):1. Review.
1023 Watson-Jones D, Oliff M, Terris-Prestholt F, et al. Antenatal syphilis screening in sub Saharan Africa: lessons learned from Tanzania. Tropical Medicine & International Health. Sep. 2005;10(9):934. Statistical Analysis. [pmid: 16135202].
1024 Waugh N, Black C, Walker S, et al. The effectiveness and cost effectiveness of computed tomography screening for coronary artery disease: systematic review. Health technology assessment (Winchester, England). 1. 41. Oct. 2006;10(39):ix-x. iii. Review.
1025 Wechowski J, Connolly M, Schneider D, et al. Cost-saving treatment strategies in in vitro fertilization: a combined economic evaluation of two large randomized clinical trials comparing highly purified human menopausal gonadotropin and recombinant follicle-stimulating hormone alpha. Fertility & Sterility. Apr. 2009;91(4):1067. Off topic. [pmid: 18339384].
1026 Wee HL, Machin D, Loke WC, et al. Assessing differences in utility scores: a comparison of four widely used preference based instruments. Value in Health. Jul Aug. 2007;10(4):256. Off topic. [pmid: 17645680].
1027 Weimer DL, Sager MA. Early identification and treatment of Alzheimer's disease: social and fiscal outcomes. Alzheimer's & Dementia. May. 2009;5(3):215-26. Costs only.
1028 Weimer DL, Vining AR, Thomas RK. Cost-benefit analysis involving addictive goods: contingent valuation to estimate willingness-to-pay for smoking cessation. Health Economics. Feb. 2009;18(2):181-202. Off topic. [pmid: 18566968].
1029 Weinberg BM, Shindy W, Lo S. Endoscopic balloon sphincter dilation (sphincteroplasty) versus sphincterotomy for common bile duct stones. Cochrane Database of Systematic Reviews. 2006;(4):004890. Statistical Analysis.
1030 Weintraub WS, Barnett P, Chen S, et al. Economics methods in the Clinical Outcomes Utilizing percutaneous coronary Revascularization and Aggressive Guideline driven drug Evaluation (COURAGE) trial. American Heart Journal. Jun. 2006;151(6):1180. Review. [pmid: 16781215].
1031 Welton NJ, Ades AE. Estimation of markov chain transition probabilities and rates from fully and partially observed data: uncertainty propagation, evidence synthesis, and model calibration. Medical Decision Making. Nov-Dec. 2005;25(6):633. Off topic. [pmid: 16282214].
1032 Werker G, Saure A, French J, et al. The use of discrete-event simulation modelling to improve radiation therapy planning processes. Radiotherapy & Oncology. Jul. 2009;92(1):76-82. Off topic. [pmid: 19356818].
1033 Whitley RJ. The role of oseltamivir in the treatment and prevention of influenza in children. Expert Opinion On Drug Metabolism & Toxicology. Oct. 2007;3(5):755. Off topic. [pmid: 17916060].
1034 Wijnen W, Wesemann P, de Blaeij A. Valuation of road safety effects in cost-benefit analysis. Evaluation & Program Planning. Nov. 2009;32(4):326-31. Off topic. [pmid: 19665228].
1035 Wilcox CM, Kilgore M. Cost minimization analysis comparing diagnostic strategies in unexplained pancreatitis. Pancreas. Mar. 2009;38(2):117. Cost Only. [pmid: 18852686].
1036 Willan AR, Kowgier ME. Cost effectiveness analysis of a multinational RCT with a binary measure of effectiveness and an interacting covariate. Health economics. Jul. 2008;17(7):777. Review. [pmid: 17764096].
1037 Willan AR, Lin DY, Manca A. Regression methods for cost effectiveness analysis with censored data. Statistics in medicine. Jan. 15. 2005;24(1):131. Off topic. [pmid: 15515137].
1038 Williams C, Brunskill S, Altman D, et al. Cost effectiveness of using prognostic information to select women with breast cancer for adjuvant systemic therapy. Health technology assessment (Winchester, England). 1. 204. Sep. 2006;10(34):ix-xi. iii. Review.
1039 Williams I, McIver S, Moore D, et al. The use of economic evaluations in NHS decision making: a review and empirical investigation. Health technology assessment (Winchester, England). 1. 175. Apr. 2008;12(7):ix-x. iii. ix. Review.
1040 Wilson AS, Goodall JE, Ambrosini G, et al. Development of an interactive learning tool for teaching rheumatology a simulated clinical case studies program. Rheumatology. Sep. 2006;45(9):1158. Off topic. [pmid: 16531436].
1041 Wimo A. Clinical and economic outcomes friend or foe?. International Psychogeriatrics. Jun. 2007;19(3):497. Off topic. [pmid: 17346367].
1042 Windmeijer F, Kontodimas S, Knapp M, et al. Methodological approach for assessing the cost effectiveness of treatments using longitudinal observational data: the SOHO study. International Journal of Technology Assessment in Health Care. 2006;22(4):460. Statistical Analysis. [pmid: 16984679].
1043 Windyga P, Kim K, White V, et al. Cost return prediction in morbidly obese employees following weight loss interventions: a study framework. Conference Proceedings: Annual International Conference of the IEEE Engineering in Medicine & Biology Society. 2007;2007:1766. Off topic.
1044 Wolf MS, Fitzner KA, Powell EF, et al. Costs and cost effectiveness of a health care provider directed intervention to promote colorectal cancer screening among Veterans. Journal of Clinical Oncology. Dec. 1. 2005;23(34):8877. Off topic. [pmid: 16314648].
1045 Wolters R, Grol R, Schermer T, et al. Improving initial management of lower urinary tract symptoms in primary care: costs and patient outcomes. Scandinavian Journal of Urology & Nephrology. 2006;40(4):300. Statistical Analysis. [pmid: 16916771].
1046 Won KJ, Agarwal S, Shen L, et al. An integrated approach to identifying cis-regulatory modules in the human genome. PLoS ONE [Electronic Resource]. 2009;4(5):e5501. Off topic.
1047 Wong D, Benson LN, McCrindle BW. Response to Commentary Ebels T, Maruszewski B, Blackstone EH. What is the preferred therapy for patients with aortic coarctation the standard gamble and decision analysis versus real results? Cardiol Young 2008;18: 18 21. Cardiology in the young. author reply 448. Aug. 2008;18(4):445. Off topic. [pmid: 18533070].
1048 Wong D, Benson LN, Van Arsdell GS, et al. Balloon angioplasty is preferred to surgery for aortic coarctation. Cardiology in the young. Feb. 2008;18(1):79. Decision aid. [pmid: 18205970].
1049 Woodhall SC, Jit M, Cai C, et al. Cost of treatment and QALYs lost due to genital warts: data for the economic evaluation of HPV vaccines in the United Kingdom. Sexually transmitted diseases. Aug. 2009;36(8):515. Off topic. [pmid: 19543143].
1050 Wroe AL, Bhan A, Salkovskis P, et al. Feeling bad about immunising our children. Vaccine. Feb. 10. 2005;23(12):1428. Off topic. [pmid: 15670876].
1051 Wu F, Sun PR, Ke HK, et al. A study of pre-decision evaluation using influence diagram: an estimation of the benefits of influenza vaccination. Journal of Medical Systems. Feb. 2009;33(1):19-25. Costs only. [pmid: 19238893].
1052 Wu LY, Zhou X, Li F, et al. Conditional random pattern algorithm for LOH inference and segmentation. Bioinformatics. Jan. 1. 2009;25(1):61-7. Off topic. [pmid: 18974074].
1053 Wye L, Shaw A, Sharp D. Evaluating complementary and alternative therapy services in primary and community care settings: a review of 25 service evaluations. Complementary therapies in medicine. Sep. 2006;14(3):220. Review. [pmid: 16911903].
1054 Wylie-Rosett J, Herman WH, Goldberg RB. Lifestyle intervention to prevent diabetes: intensive and cost effective. Current opinion in lipidology. Feb. 2006;17(1):37. Review. [pmid: 16407714].
1055 Xie F, Li SC, Luo N, et al. Comparison of the EuroQol and short form 6D in Singapore multiethnic Asian knee osteoarthritis patients scheduled for total knee replacement. Arthritis & Rheumatism. Aug. 15. 2007;57(6):1043. Off topic. [pmid: 17665466].
1056 Yabroff KR, Schrag D. Challenges and opportunities for use of cost-effectiveness analysis. Journal of the National Cancer Institute. Sep. 2. 2009;101(17):1161. Other. [pmid: 19666852].
1057 Yang F, Tong X, McCarver DG, et al. Population based analysis of methadone distribution and metabolism using an age dependent physiologically based pharmacokinetic model. Journal of Pharmacokinetics & Pharmacodynamics. Aug. 2006;33(4):485. Off topic. [pmid: 16758333].
1058 Yang Y, Sugimoto JD, Halloran ME, et al. The transmissibility and control of pandemic influenza A (H1N1) virus. Science. Oct. 30. 2009;326(5953):729-33. Statistical analysis. [pmid: 19745114].
1059 Yelin E. Is early intervention worth it?. Journal of Rheumatology Supplement. Jan. 2005;72:36. Off topic.
1060 You JH, Chan FW. Pharmacoeconomics of entecavir treatment for chronic hepatitis B. Expert opinion on pharmacotherapy. Oct. 2008;9(15):2673. Review. [pmid: 18803453].
1061 Yu VY. Is neonatal intensive care justified in all preterm infants?. Croatian medical journal. Oct. 2005;46(5):744. Off topic. [pmid: 16158466].
1062 Yukich JO, Zerom M, Ghebremeskel T, et al. Costs and cost-effectiveness of vector control in Eritrea using insecticide-treated bed nets. Malaria Journal. 2009;8:51. Off topic. [pmid: 19331664].
1063 Zaidel A, Spivak A, Shpigelman L, et al. Delimiting subterritories of the human subthalamic nucleus by means of microelectrode recordings and a Hidden Markov Model. Movement Disorders. Sep. 15. 2009;24(12):1785-93. Off topic. [pmid: 19533755].
1064 Zarate V, Kind P, Chuang LH. Hispanic valuation of the EQ 5D health states: a social value set for Latin Americans. Value in Health. Dec. 2008;11(7):1170. Off topic. [pmid: 18489516].
1065 Zethraeus N, Borgstrom F, Strom O, et al. Cost effectiveness of the treatment and prevention of osteoporosis a review of the literature and a reference model. Osteoporosis International. Jan. 2007;18(1):9. Review. [pmid: 17093892].
1066 Zhang SX, Gao J, Buchholz TA, et al. Quantifying tumor-selective radiation dose enhancements using gold nanoparticles: a monte carlo simulation study. Biomedical Microdevices. Aug. 2009;11(4):925-33. Off topic. [pmid: 19381816].
1067 Zhang SX, Gao J, Buchholz TA, et al. Quantifying tumor-selective radiation dose enhancements using gold nanoparticles: a monte carlo simulation study. Biomedical Microdevices. Aug. 2009;11(4):925. Off topic. [pmid: 19381816].
1068 Zhang W, Doherty M, Bardin T, et al. EULAR evidence based recommendations for gout. Part II: Management. Report of a task force of the EULAR Standing Committee for International Clinical Studies Including Therapeutics (ESCISIT). Annals of the Rheumatic Diseases. Oct. 2006;65(10):1312. Off topic. [pmid: 16707532].
1069 Zhang W, Doherty M, Pascual E, et al. EULAR evidence based recommendations for gout. Part I: Diagnosis. Report of a task force of the Standing Committee for International Clinical Studies Including Therapeutics (ESCISIT). Annals of the Rheumatic Diseases. Oct. 2006;65(10):1301. Off topic. [pmid: 16707533].
1070 Zheng Y. Denoising of quadrature ultrasound Doppler signal from bi-directional flow based on matching pursuit. Ultrasonics. Jan. 2009;49(1):19-25. Off topic. [pmid: 18678382].
1071 Zhou H, Isaman DJ, Messinger S, et al. A computer simulation model of diabetes progression, quality of life, and cost. Diabetes care. Dec. 2005;28(12):2856. Off topic. [pmid: 16306545].
1072 Zhou Q, Jiang N, Englehart K, et al. Improved phoneme-based myoelectric speech recognition. IEEE Transactions on Biomedical Engineering. Aug. 2009;56(8):2016-23. Off topic. [pmid: 19535319].
1073 Zhou Q, Zygmunt AC, Cordeiro JM, et al. Identification of Ikr kinetics and drug binding in native myocytes. Annals of Biomedical Engineering. Jul. 2009;37(7):1294-309. Off topic. [pmid: 19353268].
1074 Zhou X, Li F, Yan J, et al. A novel cell segmentation method and cell phase identification using Markov model. IEEE Transactions on Information Technology in Biomedicine. Mar. 2009;13(2):152-7. Off topic. [pmid: 19272857].
1075 Zitzmann NU, Marinello CP, Sendi P. A cost effectiveness analysis of implant overdentures. Journal of dental research. Aug. 2006;85(8):717. Statistical Analysis. [pmid: 16861288].
1076 Zochling J, van der Heijde D, Burgos-Vargas R, et al. ASAS/EULAR recommendations for the management of ankylosing spondylitis. Annals of the Rheumatic Diseases. Apr. 2006;65(4):442. Off topic. [pmid: 16126791].
1077 Zochling J, van der Heijde D, Dougados M, et al. Current evidence for the management of ankylosing spondylitis: a systematic literature review for the ASAS/EULAR management recommendations in ankylosing spondylitis. Annals of the Rheumatic Diseases. Apr. 2006;65(4):423. Review. [pmid: 16126792].
1078 Zwanziger J, Hall WJ, Dick AW, et al. The cost effectiveness of implantable cardioverter defibrillators: results from the Multicenter Automatic Defibrillator Implantation Trial (MADIT) II. Journal of the American College of Cardiology. Jun. 6. 2006;47(11):2310. Off topic. [pmid: 16750701].