# Verbatim Quotes from Interviews of Modelers and USPSTF Members, by Theme

Modality

Quote
“The EPC systematic reviewers and the modelers must be joined throughout the process. This was the process issue in the colon cancer study.”
“Multiple modeling groups working on the same project is ideal. There is tremendous value in the process, and the comparisons of the outcomes is essential.”
“Comparative modeling is a best practice. Multiple modeling groups should be employed in order to develop the best outputs. This allows for sensitivity analyses on the structural assumptions between models.”
“CISNET is a “model” for such collaboration…independent development of models prior to collaboration and comparisons.”
“The structure of CISNET gives the models produced credibility and validity.”
“Multiple modeling groups, same inputs, seeking to address the same problem in multiple ways.”
“Simultaneous development of the evidence report and the modeling effort.”
“Systematic review and meta-analysis should be conducted and completed first.”
“Simultaneously developing models and the reviews is suboptimal, leads to differences in parameters and assumptions.”

Communication

Quote
“Most important opportunity is to improve the communication with respect to the models.”
“Efforts should focus on increasing the understandability of models and the results.”
“Most of the model documentation and appendices are incomprehensible.”
“Seek to “tune: the comprehension to the science writer at Washington Post or NY Times. If this can be accomplished, then others can be used to communicate to a wider audience of MDs and patients…those that need to use the information on a daily basis.”
“Modelers should go through a communications / media training course in order to elevate their skills in communicating with popular media”.
“Use of multiple modeling groups is critical…this creates “convergent validity” of the outcome, assuming that the models converge on the same outcomes using the same inputs. The structure of the model is less important in the same inputs produce the same outcomes.”

Modeling Literacy

Quote
“A short manual for the TF would be helpful. Make recommendations about when modeling would be helpful.”
“Decision analysis 101 for the users/consumers is critical and should be included in every presentation to the TF, since many members rotate between projects.”
“How can we increase the capacity for modelers?”

Process / Recommendations for Future Projects

Quote
“The TF should specify the questions they want answered and how to parameterize/specify the model and analysis.”
“Specifying the tables and figures a priori helps frame the question and direct the modeling efforts to ensure that the outputs are what the TF needs to make recommendations.”
“TF was very specific with respect to the issues/questions they wanted the modeling effort to address.”
“Very helpful when the TF can be very specific about what they are asking for.”
“Collaboration with the policy makers in order to develop a better set of outputs to inform decisions and recommendations.”
“Models need to assist the TF in the primary goals. Assess the certainty of the NET benefit. Determine the magnitude of net benefits.”
“Models should be directed to the key questions that the TF needs to make and that models are well-suited to handle…Strategies concerning the start and stop age for screening and the interval for screening.”
“Colon cancer – represented the worst process but the best outcome. Breast cancer – best process and worst outcome. Cervical cancer was least problematic. The groups need to jointly inform and determine the inputs of the model. Dialogue between groups is critical.”
“Strong leadership from USPSTF lead assured alignment among the modeling and SR teams.”
“An iterative process should be used with the modeling groups and the interactions with the USPSTF. This improves the confidence and belief in the model and the results from the TF perspective.”
“Value of information modeling should be used to prioritize research spending.”
“Interaction with modelers and systematic review was essential to build quality models. Models are best suited to fill in gaps in the evidence, determine the value of information and address the ‘future’.”
“We should focus on interpreting the data and results versus spending time trying to create understanding about the modeling or models.”
“Efforts should focus on creating parity among cancers, specifically the quantification of benefits, decreasing morbidity, mortality of increasing QALY-saved.”
“Develop a consistent approach in the development and quantification of harms (e.g. unnecessary biopsies, false positive rates).”
“Consistency in the quantification of benefits lends itself to the TF goals of assessing the magnitude of benefits for recommendation.”