# General Interview Outline – Modelers and USPSTF Members

1. Evaluate the strengths and weaknesses of current approaches to conducting a simultaneous systematic review and modeling exercise.
2. Evaluate stakeholder perceived needs and whether needs were met.
3. Make recommendations for the process of conducting future similar projects.
4. Evaluate the “lessons learned” from the colorectal, breast, and cervical cancer modeling projects alongside systematic reviews.
5. Evaluate their impact on U.S. Preventive Services Task Force decisionmaking.