# Summary of Preliminary Findings Provided to Focus Group Participants

[underlined: Preliminary Findings – Summary of Key Points]

Experience with, and Attitude toward, Decision and Simulation Modeling

Evidence-Based Practice Centers Key Informants

Compiled by François Sainfort and Sean Gregory

Telephone interviews with 20 Evidence-based Practice Centers (EPC) key informants were conducted between December 2009 and March 2010.

Key points from these interviews include:

Attitudes Toward Modeling and Appropriateness of Modeling in Systematic Reviews
- Interviewees with modeling experience unanimously held positive attitudes toward modeling with respect to its benefit for EPC projects and much of the course of Agency for Healthcare Research and Quality work.
- All reported that modeling was an important set of techniques and strategies that were applicable to the work they were engaged in, and were generally supportive of incorporating these techniques into their work.
- Some interviewees seemed to struggle with whether the development of a model is within or beyond the scope of a systematic review of the literature.
- Several interviewees were supportive of including models in systematic reviews and felt it was a natural extension of the purpose and intent of the models.

Research Questions and Contexts Best Suited for Decision Modeling and Simulation
- Models are well-suited to address gaps in the literature and to synthesize literature from differing sources and contexts into a single representation of the empirical evidence.
- In many cases there are studies that demonstrate quantitative findings for intermediate effects; but studies of the long-term or terminal effects are underway, inconclusive or not feasible to conduct.
- The comparison of testing, prevention, and diagnostic strategies was also noted as a primary area in which modeling can be of great benefit.
- Most remarked that the comparison of strategies and the establishment of net benefit, that is benefit less harms, can only be determined through the use of a decision model.
- More generally, models are well suited for research questions which have a high degree of uncertainty in assumptions or input parameters; or situations in which there is a great amount of discordance between estimates in empirical studies.
- In many cases, large randomized controlled trials or observational studies have not focused on specific subpopulations. These are situations in which modeling can be used to simulate findings where subpopulation characteristics are believed to impact or change conclusions for a specific subpopulation.
- There is great interest in the benefits modeling can bring to determining the value of information and specification of research priorities and directions.

Definitions of Decision Models and Simulations
- Most converged on a general definition of decision modeling and simulation as the mathematical representation of a decision (or series of decisions) based upon empirical input parameters, supported by a specified framework or mechanism (e.g., a particular representation of the natural history of a disease), and subject to a set of identifiable assumptions.
- While the majority reported a similar definition of a model, there was greater disparity in the ability to differentiate between modeling and the domain of traditional statistics.
- Some drew distinct lines between any statistics used for “inference” and the set of techniques used in decision analysis.
- Others made more specific comments, such as decision models begin with Bayesian statistics and meta-regression and extend to the techniques more commonly employed in decision models, such as Markov modeling and simulation techniques.
- There was high agreement for the general definition, but the distinctions among techniques seemed to represent the interviewees' experiences with particular techniques in particular situations.

Evaluation of a Model and of Model Outputs
- The evaluation of a model or the determination of the quality of a model had high agreement among the group “with experience.”
- Albeit qualitative, the majority reported that their opinion as to the “quality and expertise” of the actual modeler who developed the decision model weighed heavily on their overall and initial assessment of the model.
- Most identified the lack of defined standards and methods as a major problem in the evaluation of models, and again hoped that this initiative would bring about some initial draft evaluation standards.
- When pressed for the mechanics of their evaluation of a model, most reported that they routinely inspected the quality and reliability of the input parameters, a determination of the reasonableness of the assumptions, and, if available, an evaluation of the structure of the model.
- All interviewees described the need for standardization of model outputs, as an important factor in the acceptance of models, but also in the practical usage of the models across research questions and policy issues.
- Interviewees with the most extensive reported experience also discussed the need for standardization of the presentation of model results in addition to the outcome metrics reported.

Models and Simulations Results as a Form of “Evidence”
- Interviewees with modeling experience stated that the outputs from a model that are included in a systematic review are indeed evidence, and should be considered as such.
- The rigor of the systematic review methodology ensured high quality parameter inputs to these models, as well as sensitivity analyses and model assumptions, that were consistent with the state of the science according to the literature.
- Interviewees did make statements that this evidence was “manufactured” or “model-produced” evidence, possibly indicating the need to categorize it as a different type of evidence.
- Interviewees did not believe that the current evidence grading methodologies addressed the issues that model and simulation evidence present to a reviewer.
- Interviewees without experience with models and simulation pointed to this lack of evidence standards as the principal reason to exclude any modeling studies from systematic reviews.
- Several reported that even if standards existed, the incorporation of models as evidence was beyond the scope of systematic reviews, which are charged with the compilation of all the available empirical evidence, and thus by definition exclude “modeled” or “simulated” data.
- Those without experience explicitly stated that models and simulations were not on the same “continuum of evidence” as other studies and sources and, in fact, represented a very different data source, the merging of which with traditional evidence, created a number of issues.