# Focus Group Instructions

Conducted by François Sainfort, Ph.D., May 16–17, 2010

HILTON ATLANTA, 255 Courtland St. NE, Atlanta, GA 30303

Participants:

- Alan Brennan
- Andy Briggs
- Peter Neumann
- Mark Sculpher

Background: The overarching goal of this project is to provide guidance to determine when incorporating a decision-analytic and/or simulation model alongside a systemic review would be of added value for decision making purposes. Currently, Evidence-based Practice Centers (EPCs) review and synthesize scientific literature on a particular topic in the form of evidence reports and technology assessments to assist public and private organizations in developing strategies that improve quality of health care and decision making.

However, often there is not enough evidence to fully address the questions that are relevant for decisionmakers. Or, there may be enough evidence on several components to the decision (e.g., diagnostic test characteristics, test risks, risk and effectiveness of treating disease) but no studies that evaluate the relevant clinical strategies that incorporate all of these components and are most important for decision making purposes. In such situations, a decision or simulation model can add value to the systematic review.

Focus Group: The goal of this focus group is to gather modeling experts to elicit, characterize, and qualify best practices in decision and simulation modeling in the context outlined above. Elements to be discussed and addressed include:

- model formulation and characterization,
- model development and construction,
- handling and presentation of modeling assumptions,
- definition and presentation of parameters,
- outcomes to incorporate into the model,
- model analysis,
- model testing, validation, and
- model implementation, including results presentation and communication.

Materials attached in preparation for focus group:

Preliminary Findings – Experience with, and Attitude Toward, Decision and Simulation Modeling

Selection of three articles on best practices in decision and simulation modeling:

1 Braithwaite, et al. Incorporating Quality of Evidence into Decision Analytic Modeling. Annals of Internal Medicine. 2007;146:133-41.
2 Cooper, et al. Use of Evidence in Economic Decision Models: Practical Issues and Methodological Challenges. Health Economics. 2007;16:1277-86.
3 Philips, et al. Good Practice Guidelines for Decision-Analytic Modeling in Health Technology Assessment. Pharmacoeconomics. 2006;24(4):355-71.