# Search Strategy for Best Practices Papers

Figure G1 Literature flow diagram

This is a flow chart summarizing the search and selection of articles for the literature on modeling best practices: There were 616 citations identified in Medline using the search strategy developed for this project. Of these, 593 were excluded because the articles did not pertain specifically to best practices. We also ran an update of the search strategy used in the Phillips et al. review of good practice guidelines. That search yielded 305 articles, of which 292 were excluded. An additional 6 articles were located from a hand search of relevant journals. This totaled 42 full text articles pulled for a final screening, of which 3 were excluded. The final literature set totaled 39 articles.

A search performed in October 2010, with the search string provided below, yielded 334 articles. An updated search run on March 3 yielded an additional 282 articles.

Search Term | # articles
1 decision analytic model$.mp. | 681
2 decision model$.mp. | 909
3 simulation model$.m | 3,523
4 markov model$.mp. | 3,135
5 state transition model$.mp. | 149
6 markov cohort model$.mp. | 15
7 1 or 2 or 3 or 4 or 5 or 6 | 8,253
8 guideline$.mp. | 180,168
9 best practice$.mp. | 4,970
10 good practice$.mp. | 1,535
11 guidance.mp. | 38,596
12 8 or 9 or 10 or 11 | 219,108
13 7 and 12 | 334

We also updated the search used in the Philips et al. (2004) review using the following search strategy:

1. (checklist? or check list? or standards or standardi?ation or peer review$ or rules or correct$ or bias or fundamentals or recommend$ or best or strength$ or weakness$ or quality or qualities or validity or guideline? or validation or checkpoint?).ti. | 286,767
. (properly or critically appraise or problems or limitations or rating scale? or framework$ or protocol? or audit or principles or methodolog$).ti. | 17,5148
3. (validate or validation or evaluating or properties or guidance or integrity or evaluation or pros or cons).ti. | 429,234
4. (decision adj (tree or triage or data or analytic or analysis)).ti. | 1,516
5. *“models, economic”/ or *“models, econometric”/ | 2,467
6. (*“decision support techniques”/ or *“data interpretation, statistical”/ or *“decision theory”/ or *“models, statistical”/ or *“likelihood functions”/ or *“linear models”/ or *“logistic models”/ or *“proportional hazards models”/) and *“costs and cost analysis”/ | 14
7 ((economic? or pharmacoeconomic? or decision? or cost? or costing?) and model$).ti. | 2,789
8 (markov or crystal ball).ti. | 1,522
9 *“markov chain”/ | 1,089
10 ((markov model$ or economic model$ or mathematical model$ or cost$ model$ or pharmacoeconomic model$ or decision model$) adj2 (checklist? or check list? or standards or standardi?ation or peer review$ or rules or critiquing or criteria or good or bad or correct$ or bias or fundamentals or recommend$ or best or strength$ or weakness$ or quality or qualities or validity or guideline? or validation or checkpoint?)).ab. | 137
11 ((markov model$ or economic model$ or mathematical model$ or cost$ model$ or pharmacoeconomic model$ or decision model$) adj2 (properly or critically appraise or problems or limitations or rating scale$ or good practice$ or framework$ or protocol$ or audit or principles or methodolog$)).ab. | 102
12 ((markov model$ or economic model$ or mathematical model$ or cost$ model$ or pharmacoeconomic model$ or decision model$) adj2 (validate or validation or evaluating or properties or guidance or integrity or avoiding bias or evaluation or pros or cons)).ab. | 97
13 ((decision tree or decision triage or decision data or decision analytic$ or decision analysis or crystal ball) adj2 (checklist? or check list? or standard$ or peer review$ or rules or critiquing or criteria or good or bad or correct$ or bias or fundamentals or recommend$ or best or strength$ or weakness$ or quality or qualities or validity or guideline? or validation or checkpoint?)).ab. | 99
14 ((decision tree or decision triage or decision data or decision analytic$ or decision analysis or crystal ball) adj2 (properly or critically appraise or problems or limitations or rating scale$ or framework$ or protocol$ or audit or principles or methodolog$)).ab. | 117
15 ((decision tree or decision triage or decision data or decision analytic$ or decision analysis or crystal ball) adj2 (validate or validation or evaluating or properties or guidance or integrity or evaluation or pros or cons)).ab. | 30
16 ((economic evaluation? or economic analysis or economic stud$ or economic submission?) and guideline$).ti. | 47
17 or/10-15 | 558
18 or/4-9 | 7,805
19 or/1-3 | 849,212
20 19 and 18 | 813
21 16 or 17 or 20 | 1,389
22 limit 21 to yr=“2003-2006” | 351
23 limit 22 to english language | 326
24 limit 21 to (english language and yr=“2007-Current”) | 308