# Types of Systematic Reviews

## Overview

There are two broad categories of AHRQ-funded synthesis reports, Technical Briefs and Research Reviews. Technical Briefs are short reports on the type of information available to answer a question, whereas Research Reviews are more traditional comprehensive systematic literature reviews with quantitative and qualitative summaries of the actual evidence for each key question. AHRQ funds several different types of Research Reviews, including Comparative Effectiveness Reviews (CERs), National Institutes of Health (NIH) Consensus and State-of-the-Science Conference reviews, U.S. Preventive Services Task Force (USPSTF) reviews, and some additional Generalist Program reviews. Below are descriptions of each of these different types of reports.

## Technical Briefs

The aim of a Technical Brief is to provide an overview of the information available on a given topic. Typically these are early stage products for which there is only limited evidence. The goal is to explain what is known and not known about new or emerging health care tests or treatments. These reports can be used to help set priorities for future research needs and to help develop questions for future more comprehensive reviews. It is not anticipated that modeling would be done for a Technical Brief.

## Comparative Effectiveness Reviews (CER)

The CER is the core product of the Effective Health Care (EHC) Program and an area where we would anticipate a great deal of interest in the use of decision models. The aim of a CER review is to depict how the relative benefits and harms of a range of options compare, rather than to answer a narrow question of whether a single therapy is safe and effective. This requires a clear understanding of the clinical context to ensure that the review focuses on the appropriate population and interventions among which clinicians are currently choosing.

There is rarely a sufficient body of head-to-head trials to support easy conclusions about comparative benefits and harms. Providing useful information requires examining a broader array of literature, including placebo-controlled trials and observational studies. The latter are especially useful for looking more completely at harms, adherence, and persistence. In addition, reviews may examine whether, in the absence of head-to-head trials, indirect comparisons may be useful, e.g., comparing results of placebo-controlled trials of A and placebo-controlled trials of B.

Carefully examining the applicability of evidence is especially important. A useful review compares the tradeoffs of multiple alternatives, each of which may vary with the underlying population and setting. Evidence on harms is often hard to determine from tightly controlled randomized trials. Observational studies provide another check on whether results observed in trials appear to hold up under more representative settings and populations.

The interpretation of the evidence and the limits of interpretation are important. Equivalence of different treatments for a group of patients on average does not necessarily imply they are equivalent for all individuals. Attempts to explore subgroups for which benefits or harms of specific interventions vary may be needed. Often, however, there is limited evidence to support strong conclusions about the specific benefits of a particular intervention for subgroups.

## U.S. Preventive Services Task Force (USPSTF) Reviews

The EPC conducts systematic reviews of the evidence on specific topics in clinical prevention that serve as the scientific basis for USPSTF recommendations. The USPSTF reviews the evidence (including contracted systematic review), estimates the magnitude of benefits and harms for each preventive service, reaches consensus about the net benefit for each preventive service, and issues a recommendation. Recently, the USPSTF used cancer modeling output, in addition to systematic reviews, to update of their cancer screening recommendations for colorectal, breast, and cervical cancers.

## NIH Consensus and State-of-the-Science Conference Reviews

These reviews are contracted to provide an evidence-based, unbiased systematic review for upcoming NIH Consensus Development or State-of-the-Science Conference sponsored by the Office of Medical Applications of Research (OMAR). Consensus Development Conferences are typically undertaken when there is a solid body of high-quality evidence (randomized trials, well-designed observational studies) and it is reasonable to expect that the panel will be able to give clinical guidance. State-of-the-Science Conferences are generally utilized in cases where the evidence base is weaker and the sponsoring NIH Institute or Center is seeking the panel's opinion on future research priorities. The role for modeling in these settings is unclear.

## Generalist Program Reviews

The EHC program also funds some additional reviews that do not fit into the CER, USPSTF, NIH Consensus and State-of-the-Science review programs. This general topic category can represent a wide array of topics and large range of quality of evidence in the existing published literature on the topic. We would anticipate that the use of models would be relevant to several topics from generalist program reviews.