# Verbatim Quotes for Key Themes

This appendix summarizes the results of the Elite Interviews conducted with EPC directors and staff. Tables D1–D8 provide de-identified verbatim quotes for each theme presented along with clarifying comments and discussion from the interviewers.

Table D1 Theme #1: General attitude towards modeling

Respondent | Quote
16 | “Lack of experience with modeling…when we have the need to incorporate modeling, we've had to seek outside expertise.”
15 | “We've been doing models for 8 years, going back to the inception of the EPCs…we feel that they are a very important part of EPC work, and a natural extension of EPC work.”
10 | “Default should be a model in every CER report.”
7 | “No modeling experience and no intent either.”
4 | “No clear guidance from methods manual on how to address…low modeling expertise within EPC…need guidance from AHRQ in order to assess.”
| “Models are useful if they change the scope of CERs from systematic reviews to guidelines…any step closer to the establishment of a guideline…usage of the guideline by someone other than researchers.”
1 | “We have not done much modeling but we are quite interested… possibly through collaboration with others.”

Table D2 Theme #2: When to utilize models

Respondent | Quote
16 | “When the outcomes are in doubt, when there are many covariates that might affect the outcome… a model would be very helpful.”
15 | “Uncertainty about outcomes, benefits, harms…” “Extrapolation to groups that have not been well studied.” “Determining the benefits of increased accuracy of tests versus decreasing access by recommending screening.” “Situations where the evidence is poor, or where later stage outcomes are not well understood.” “Task force review…these issues are particularly well suited.”
13 | “Anytime there is uncertainty in the data or the situation.” “Addressing evidence gaps.” “Unclear disease progression, like the ovarian cancer project, where the natural history of the disease is unclear.” “Where there are not enough trials in the evidence, this makes the results from screening tests clearer.” “Where results are insufficient but are handled as a positive indication.”
11 | “In the case of what works type of questions…in determining effectiveness from multiple RCTs.” “In cases where there is less real data…like H1N1…to inform questions of prevalence or containment.” “Where there is a lack of quality data about outcomes…where we have surrogate vs. terminal outcomes.” “Value of information modeling is underexplored…this could be the most useful area.”
10 | “Quantify the effect of a lack of evidence…for example the characteristics of screening…frequency and costs. “In situations where there is a lack of evidence.” “Low evidence situations where the causal chain and probabilities are difficult to assess without models.” “To assess value of information…and to allocate additional research resources.”
9 | “Working to incorporate models in all proposals…understand the economic valuation of the RCTs.” “Simulation models with underlying cost effectiveness should be included in reports.” “Models should be used to update findings or to replicate results.” “Clearly defined clinical questions.”
8 | “Evaluation of diagnostic tests beyond simple specificity and sensitivity…treatment decisions…comparing treatment strategies where optimal treatments are unclear…allocation of resources…cost effectiveness…value of information.”
7 | “CERs that have design or heterogeneity issues…use modeling, specifically simulation and bootstrapping to improve the value of evidence in CER.” “When you need to synthesize evidence from multiple data reports, use simulation to understand the impacts these inputs have.” “Determining the value of information.” “Disease progression simulation helps understand the phenomenon.”
6 | “Weak evidence, very complex clinical issue…evidence is poorly documented…all complex clinical pathways.” “Multiple outcomes…outcomes that are different among subgroups.”
5 | “Models are state of the art for cost-effectiveness…evaluation of diagnostic testing…treatment questions…linking surrogate to terminal outcomes” “Determining the treatment of subgroups of targeted populations with different outcomes.”
4 | “Comparison of alternative strategies…economic or clinical decisions.” “Gap between intermediate and long-term outcomes.” “Optimization decisions…defining treatment specifics.”
3 | “Situations where landmark clinical trials have not been conducted…unclear balance between evidence and harms…the focus of the decision is on costs…to determine the value of research gaps.” “Models in technology assessments are a limited context.”
2 | “Extremely useful when we do not have all the answers from the literature. Very strong evidence form models for situations involving frequency of screening.” “When we do not have an adequate answer from the systematic review but some of the evidence can provide input to a model.” “When we get very good evidence on how different treatments compare on benefits and harms but we need to go to the next step of putting it all together in one common metric such as QALYs. Modeling is really useful to identify treatment that provides the best overall value.” “Also to address to a question that is related to the value of information modeling especially when we are looking at questions of future research. With value of information modeling, we can figure out which one of those questions are really the most important to answer.”
12 | “Very useful when important tradeoffs exist and there is a need to balance them in some way… When there is uncertainty that is crucial to a decision, that is, the importance of ignorance, understanding what you do not know… modeling value of information to guide future research… cost-effectiveness.
14 | “One area is a situation in which studies available have only intermediate outcomes that do not reach clinical outcomes. The only way to make a stronger case is to do some modeling that looks at the relationship between the intermediate outcomes and the clinical outcomes. One could even use non-empirical data sources to build parts of the model.” “Another area where you could use modeling very effectively is when you have infinite variation in small differences in techniques and where you have two literatures that converge. One literature is the clinical literature, which is very rich in information about the treatments and very poor in information about the client. The other literature is from epidemiologists, which is very rich in information about the patients and very sparse in information about the treatments. Modeling might at least help in pointing to where future work might be more useful in merging those two streams and actually get information about how different treatments might affect different kinds of patients.” “The other area is in cost-effectiveness. In one study we developed a cost-effectiveness model which showed that the question of which type of outcome would be more beneficial from a policy standpoint depended on whose perspective one would take—the hospital perspective would be different from the insurer perspective.” “When it appears that we have a number of disjoint findings but a sense of the pathway that leads to the outcome of interest, then some kind of modeling exercise would be very helpful in trying to pull of these things together.”

Table D3 Theme #3: Model definition

Respondent | Quote
16 | “Modeling the type of decisions make clinically? Actually, any type of meta-analysis is technically a model.” “I am not used to the term around here, since we don't do much of it, so I don't have a good answer.”
15 | “Models are fundamentally a representation of a decision with respect to a hypothesis…versus an inference from statistical analysis.” “It's the mathematical analysis of a decision.”
13 | “Mathematical representation of decision alternatives and outcomes.”
11 | “A predictive component and multiple inputs…meta-regression is a model.”
10 | “Simulation of the natural history of disease and strategies to treat the disease. “Not tools for cost effectiveness… more focused on clinical questions, clinical outcomes.”
8 | “Mathematics that link two pieces of evidence.” “Define broadly to include more statistics beyond modeling.” “Has to be something that pieces together different kinds of information… and uses something relatively complex… beyond a simple formula… For example, calculating the attributable fraction of a gene for a particular disease given X, Y, Z is not really a model.” “Decisional context needs to be well thought of… if the context is not well defined or if information on treatments and/or treatment effects is lacking, a model would not help.”
3 | “Research contexts have not lent to the use of decision analytic models…we are eager to use modeling.”
2 | “A model is something that aims to answer a particular question using data input either available from empirical literature or based on assumptions that has a number of different options or comparisons. There is some type of comparison there, comparing one thing to another.”
12 | “Can be a relatively straightforward spreadsheet if benefits and harms are short term… Most of hard problems have either benefits or harms occurring over time… Need to use a decision analytic framework… Statistical models should not be included, the focus is on making a decision of some sort.”
14 | “A model is something that works around a decision tree with nodes and information that allows you to extrapolate from the data you have to answer a question for which there is no specific data. In many parts of medicine there are so many branches and potential points of disjuncture that you could not do empirical research that would capture all those things.” “A model gives you guidance in ways you can fall back to say what things are going to make a difference and what things are not. It is partly a decision making tool, a planning tool, and an evaluation tool that gives you some insight into what is likely to happen or how big the difference is needed to actually make an ultimate difference. You can make some estimation of effects at various points of the care pathway to gauge whether there is a big enough difference or it is likely to be big enough to worry about it. Hopefully you can expedite the future research agenda you might want to recommend.” “Comparing models and statistics, a model has a structure. Statistics may be a tool you would use in modeling and you may use statistics without modeling. For example, you would use statistics to calculate the likelihood of events representing real or significant events whereas a model really focuses on trying to look at the sequential effect of effects and/or activities on the prior probability of an outcome.”

Table D4 Theme #4: Model outputs

Respondent | Quote
15 | “QALYs are an artifact of the mid 90s as a result of the Gold book for CE.” “Modeling is usually from a societal or population basis…that's the reason why QALYs make sense.” “QALYs are to determine resource divisions at the broadest level.” “QALY is really an omnibus measure for everything other than dollars.” “Cost per QALY across services is the current method for reporting models.” “Morbidity or mortality are very important, we just need a method to equate them to QALYs.”
13 | “Engaging the stakeholders throughout the process is key; that makes it easier to obtain support for the outputs or recommendations.” “There should be two levels of output…simple metrics and a technical appendix.” “Clearly stated assumptions, inputs and sensitivity analyses are essential.” “QALYs and life expectancies are primary outcomes.” “Outputs depend on the decisions being made.” “Different stakeholders need different outputs…it's about the decisions they are making.” “Models with multiple outputs…providers need NNTs…patients need life expectancy, risks for adverse events.”
11 | “AHRQ needs to standardize outputs.”
10 | “QALY is the accepted standard…so you need to make it an output of the model regardless”. “QALYs do not provide a lot of utilities for specific issues.” “Outputs that are denominated in intermediate versus terminal outcomes are difficult to interpret…not sure what conclusions can be drawn.” “Developing tables that detail intermediate outcomes that change with different strategies can be very useful.” “Patients and clinicians need outputs that illustrate the tradeoffs for specific decisions.”
9 | “Model results should not just be the model outputs…more about the over intent…relevant to the stakeholders.” “Costs need to be considered.” “Clinicians are detached from most economic components.”
8 | “QALY and expectancies, but they are difficult to determine.” “Costs…but we've been asked to keep them out of scope.” “Need to additional information.” “Counts of events…like NNTs.” “QALY is most effective, because it is what everyone uses.” “Most reports stop short of QALYs to determine effect of different screening strategies.” “Outputs are situation specific…surrogate versus terminal outcomes need to be understood and identified.”
7 | “Policymakers are more apt to use decision modeling…much more than clinicians.”
6 | “Presentation of the model is critical…all caveats about inputs and any poor quality data.”
5 | “Consistency and standardization are key.” “QALY…can be a weak link to outcome decision…needs a consistent application of methods.” “Patients and providers need a chain of understanding; clinicians don't understand QALYs and can't apply them to patients.”
4 | “Physicians prefer a narrative to a table of outputs or simulation results.” “Health care decision makers do not like models…they want a recommendation.”
3 | “QALYs are the standard outputs…they are difficult for general audiences.” “Direct or patient estimate probabilities would be very helpful…an explicit model that produced confidence intervals.”
2 | “Would love to see model output presented in terms of QALYs because that's an output that is extremely meaningful and can be compared across interventions.” “Beyond that, outputs can be so varied depending on the situation, and some can be difficult to understand.”
12 | “It depends on purpose of the model. However, in general, I favor models with QALY as an output… For example for HIV intervention, treatment, or screening, one can look at infections averted as an output but then one cannot compare prevention with treatment.” “QALYs capture changes in length and quality of life and allow comparison across interventions.” “Other outcomes are important. Some metrics show benefits, others harms. One needs to delineate the pros and cons of different outcome measures. For example, successful treatment of HIV could [underlined: increase] prevalence.”
14 | [In looking at output generated by a model as a source of evidence in a systematic review,] “We would probably treat it differently. Not sure exactly how, but it would depend on what we were doing… we can't really use model outputs in our meta-analyses, but you could certainly put them into a forest plot… and certainly if their findings were different, you would discuss the discrepancies.” “What's interesting is that if a model that was used was using data from other studies that are part of the review, I am not sure what to do since the rules of the report are that each study can only be used once… This is a methodological issue that needs to be discussed.” “For users—patients, clinicians, policymakers—showing a model is a waste of time… What you have to show them is what the model says… and make sure they understand what the model says and what the model does not say, and what it means… For patients… most patients do not distinguish anything about data sources or analysis sources… they are looking for a bottom line. A model for them is just another piece of information.” “We, as academics, absolutely refuse to acknowledge that most users don't want to read more than a page of anything… as a result, we are terrible communicators.”

Table D5 Theme #5: Evaluation of models

Respondent | Quote
16 | “Formulation…how are they justifying the assumptions and the parameters…are they incorporating all the data…how was the weighting determined.”
15 | “Inputs, parameters, and sensitivity analysis are key to evaluating models.” “The structure of the model must be well documented…it is important to be able to evaluate the underlying structure of the model…how well does it characterize the pathway or natural history of the disease.” “What journals use as transparency vis a vis publishing standards is a good place to start.” “Models need to be based on a good CER…credibility is lost when modelers use expert judgment.”
13 | “The structure of the model.” “Do the results map to what we know about the data…modeling is an iterative process…how is the model performing?” “Who is the modeler…this is unscientific, but if I know who the modeler is, and if I know they do good work, then I am confident in the model.” “Then there are specifics…representation of the available alternatives…assumptions and tests…exploring the uncertainty…a conservative view…what are the results of the sensitivity analysis…what are the inputs, evidence…what data was used.”
10 | “Review the structure of the model and the basic assumptions…what are the technical aspects of the model…review the data used as inputs.”
9 | “Understand the intervention…clear specification of the model and the framework.”
6 | “Inspect the analytical framework…clear model specification is critical.” “The criteria is similar to that for any primary study.”
5 | “Traditional sources from decision analysis and cost effectiveness should be used.” “The Weinstein text is a good source.” “Model construction needs to be assessed…then sensitivity analyses need to be reported.”
4 | “Assumptions and where they break down…relative versus absolute nature of the measures…utility of the model outputs by non-modelers.”
3 | “We hope to be able to determine the model validity or quality…but it is very challenging.”
2 | “I like to see a detailed description of model inputs and assumptions that went into it.” “A lot of description about sensitivity analysis especially for input and assumptions that were based on evidence that was not as strong.” “Are data input valid? Is there an appropriate search strategy to find data? Are calculations adequate? Are appropriate sensitivity analyses conducted?”
12 | “I look at both the structure and the fidelity of the model… The latter is to judge the representation and can be very difficult.” “Need to judge the evidence of the input parameters… This can be done in just the same way as any other evidence review.” “Judging the caliber of a model is very difficult… Checklists are OK, but more important is who developed the model.” “For complex model, one should develop an enormous amount of time debugging, testing and exercising the model… It would be helpful to understand how much time modelers spent on this.”
14 | “Grading scheme for grading models has to be different from the grading scheme for grading empirical evidence. However, the grading scheme for the value of evidence needs a coherent whole but before you could really do that, you would need to define different types of models. For certain types of models, a proportion of data is empirical, some of it is opinion… the proportion would affect how you view the model as well as the evidence of the model.” “If no modeling expertise, can only tell you whether the model is useful. So, first I need to understand the model. Are the right nodes in there? Is the important information used and addressed by the model? Then, have I learned anything? Leave it to other people to evaluate whether the right type of model is used and whether it is technically sound. I trust other people who have that kind of expertise.”
1 | “Definitely do a lot of sensitivity analysis. Should even be done with systematic reviews… For example would we get the same result in a systematic review if we take one study out? Sensitivity analysis in meta-analysis.”

Table D6 Theme #6: Continuum of evidence

Respondent | Quote
16 | “Most decision models incorporate evidence from RCTs and observational studies, so it's hard to distinguish them?”
15 | “This is the gap between the U.S. and the U.K.…RCTs because of the FDA are predictable and that means credible. The value of RCTs is overstated, but the value is that they are predictable. If there were clear standards for decision models like at NICE, there wouldn't be such a perceived difference.” “The tradition of the ACP is to use models as evidence to support decisions versus those in the Evidence-based/Cochran tradition that are more wedded to methodological standards and not decisions.”
11 | “I would never use modes in a CER.” “Fifty percent of all CERs don't contain any analytics.” ‘Models are only pertinent with analysis…they are strictly quantitative.”
10 | “Where there is enough literature on a topic to create a good model, you don't need a model in the CER as evidence.”
9 | “Often there is not much evidence for the specific clinical area…many areas are uncommon.”
8 | “Typically excluded…research questions ask specifically for empirical evidence…often we comment on modeling studies, but don't include them.” “There is no mandate to include models in reports…the evidence grading process doesn't work for models.”
7 | “Our TEP was recently against the use of evidence from models in the review…just a few years ago all AHRQ reports were based on RCTs…models can be used in literature review, but not for estimating effects.”
6 | “Depends on the research question.”
4 | “Models are reviewed in the discussion section in many reports.” “Currently rated the same as no data, since the grading process doesn't allow for models.” “It's critical to report the assumptions of the model…models are informative versus evidentiary.”
3 | “Our preference is for other type of evidence, except in the evaluation of pharma and cost effectiveness or comparative effectiveness studies.” “Intermediate uncertainly is when modeling has the highest utility.”
2 | “Not quite the same level of evidence. In comparing output of a model and output of a well-designed effectiveness study, I would rate the level of evidence lower.”
12 | “I disagree with the statement that “models are not evidence”… modeling does extent evidence. Modeling studies should be included as evidence, as long as the models are good. In fact, they can be the most informative type of evidence… The USPSTF has models. The problem is that there is no well developed system for incorporating models as evidence.” “Nobody is doing an RCT to follow HIV people for 20 years. Modeling, if carefully appraised, should be included as evidence… Modeling is not a substitute but there are situations where it is the only way. We typically would not use a model for comparing drug A versus drug B, but there might be some tradeoffs for drug A versus drug B that can lend themselves to modeling.”
14 | “The weight of information/evidence provided by a model in the context of a systematic review will vary greatly with the audience. Different audiences will give different amount of credence to these models depending on what they need. As everything we do, it has to be explained in terms that are meaningful to the person you are trying to communicate with.” “Models are not empirical research, nor are we going to all the empirical research to support every clinical decision. So, somewhere we have to find some way to work our way through this. It may well be that models, either on a temporary or quasi permanent basis, may be useful in some cases in writing guidelines.” “Placed in some sort of evidence hierarchy, something that is purely empirically based will be at the top, and something that is opinion-based would be at the bottom. Something that uses modeling, even where some of the nodes rely on opinion, would be better than purely relying on opinions.”
1 | “People should realize that even an RCT has underlying theoretical perspective, just as models do.” “There seems to be a chasm between research based on empirical data and theoretical research such as modeling… Maybe the Bayesian approach can help bridge that gap.”

Table D7 Theme #7: Appropriateness of models in comparative effectiveness research (CER)

Respondent | Quote
15 | “Models are a natural extension of CER work…all models need a strong CER as the basis for inputs, assumptions and parameters.”
13 | “This is an important question…we need guidance on how to consider models in these reports.” “Models can add support to existing RCTs included in reviews…They identify opportunities for more information…This is critical in determining the value of information.”
11 | “It's reasonable to consider and include models, especially when updating previous CERs…when implementing the findings from a CER.” “Could be useful to perform rapid reviews when new information is available…like from a new RCT…how does it impact the current state of the literature?”
7 | “We need guidance from AHRQ on this issue…and guidance on how to evaluate models.”
5 | “Reluctant to include in CER…it's a substantial effort and we have limited resources.” “Purpose of the CER …identify, review and synthesize original data from empirical studies…outputs from models are a very different evidence type.” “For cost effectiveness, models are the only type available.” “We have enough problems integrating the empirical studies…we need to use careful justification for selective inclusion of models.”
4 | “CERs are well accepted by payers and providers and provider organizations. They influence the development of guidelines…we need to be cautious if we substantively change them.” “Models should be a separate part of the report…the other sections should not rely on them and should be able to stand alone.”
3 | “AHRQ needs to issue some guidance to EPCs about when the use of modeling is appropriate.” “Modeling has the ability to inform the decision…many situations have a modest body of information to model from.”
12 | “Comparative effectiveness is more than looking at the literature… Models are extremely appropriate and needed… There are many instances where the value of a systematic review would be significantly enhanced by integrating it into a model… especially in how we weigh harms and benefits… in this situation, a model increases the usefulness of the review but it needs to be transparent.”
14 | “In the context of systematic reviews the appropriateness of models varies with where you are. Some reviews are pretty straightforward and you do not need models. At one extreme you have reviews with strong evidence and the other extreme the literature is terrible and all you can do is make recommendations for future research. Then you have a group in the middle where you could extend the clinician's appreciation of what would be worthwhile at the next step of research by estimating the likely effect of the next increment of information along with some boundaries on how large that effect is likely to be or would have to be to make a substantial difference in the outcome of interest.” “The other way to do it is to say we have information up to this point but in fact we want to go beyond this point so then we need to extrapolate the information you have and modeling can be useful to do that.” “Guidelines about what are the ranges of models and situations that they would be appropriate for would be useful… Something about what should go into a model. However there is no consensus about what constitutes a good model… Disconcerting that the best indicator of the quality of a model seems to be who did it! It does not feel me with optimism that guidelines are the way to go but there may be some principles that you may want to get across. Alerting people that there is more than one kind of model and what it does and what it does not do would be valuable.”

Table D8 Theme #8: Impact of modeling effort on resources, training, timelines etc

Respondent | Quote
16 | “Models add to the time burden completing reviews…We don't have much time to get these projects completed.” “Modeling increased the timeline for the project 20–40 percent, but we outsourced to another center.” “Decision to use modeling came very early in the project.”
15 | “Modeling doubles the effort and time on a CER for AHRQ.” “It requires the division of the team into two parts…people focused on evidence review, and then the people building the model.” “This requires both teams to collaborate.” “Models require upfront development of the scope and definition…you need to know the availability of the parameters in order to specify the model.” “We need to use the VA model, where there's a national center to disseminate the expertise and methods and support and consult with the other centers.”
13 | “Identifying the opportunity for a model is difficult before the question refinement stage.” “TOs need to be more flexible to changes after this phase.” “Models take 1–2 additional team members.” “Modelers need to be involved in the CER…they need to participate in the general investigation.” “Models can be built simultaneously…it doesn't require a sequential process.”
11 | “Modeling needs to be handled in a separate TO…it's just too hard to predict the costs during the initial process.” “Modeling has a moderate impact to timelines and budgets…data need to be looked at in order to determine if models are appropriate.”
10 | “Models need to be a collaborative between clinicians and modelers.” “Collaboration builds expertise in the modelers for specific clinical issues…modelers need to focus on specific areas where they have some background-specific diseases or patient populations.” “Models need to be specified upfront and incorporated into the RFP responses.” “Model approaches and uses need to be identified ahead to time…otherwise the questions in the TO are so numerous that they consume all the report resources.” “Recent models…approximately 30 percent of the total effort.” “Expertise should be in the EPCs to conduct the modeling.” “We should be identifying subject matter modelers that can contract with other EPCs if necessary.”
8 | “A comprehensive modeling approach is resource intensive.” “Modeling is complementary to CERs…it leverages CER evidence…but it has a life of its own.” “Training is fine, but it can't substitute for experience.” “In-house modeling expertise is great, but at least EPCs need access to the talent and resources.”
7 | “Models must be considered at the inception of the project.” “Training is critical if AHRQ wants more models, or to include models as evidence…training is needed to build capacity…a methods manual for models would be helpful.” “Need clear requirements.” “Modelers need to be involved at the start of the project…joint development of analytics and review framework.”
5 | “Scope of work needs to specify whether models need to be included…with commensurate increases in funding and timeline.” “There needs to be agreement that there is a need for the increased level of evidence from models.” “Needs to be integrated into the overall review…must be used to define the questions…reviewers need to understand what the modelers need.” “An addendum or separate methods manual is required…needs to specify how to include models in the review report.”
4 | “Separate groups into reviewers and modelers.”
3 | “Models need to be specified in the question refinement phase of the project.” “CERs are very time consuming, modeling significantly increases the scope.”
2 | “Modeling will affect timeline much less if we knew up front that a model needs to be done. Could affect the timeline by two to four weeks from the time.” “Much like we have a methods manual for comparative effectiveness, there could be a method manual for commonly used types of modeling.” “Challenges include whether the right people are available on short notice since modelers are not currently part of our EPC core staff.” “Our initial approach is to have the modeling team involved from start to finish… One person from the modeling team is there more intensively at all meetings and then we'll have two other senior modeling individuals involved once a month.”
12 | “Not cheap to do this… It depends on the problem… Our most complicated models easily cost in the hundreds of thousands of dollars… Some models are the result of over 15 years of development… Engaging in a modeling effort should not be an afterthought… Developing a good model is substantial work.” “I would estimate a model can take a third to a half of the budget and effort of a systematic review. It can be a substantial additional effort depending on what the model is addressing and what the problem is, infectious disease, chronic disease, long term outcomes or not, etc.” “Not all EPCs have modeling resources… We should have collaboration between EPC in that regard… It would be useful to train additional people to do modeling. For example, we could have a CER fellowship program to increase capacity and send selected individuals to centers of excellence or institutions capable of training such people. It is a significant issue, there simply does not exist many people who have the training and skills to develop models.”
14 | “The need for a model can be recognized early on in a systematic review but you may or may not recognize it at the beginning… Probably three months in when you have done preliminary review of the literature, you can pretty much tell what your outcome variables are and if they are not the outcome variables you are looking for, then you know something like a model might be needed.” “Need to negotiate bigger budget, or ask for additional budget, or build in contingency clause for additional budget if both sides recognize the need, or do add-on after project is done.” “Obviously need some model-based training… but that's only one piece. Part of this is just to broaden people's horizon… At least, at one of those EPC meetings, there should be a modeling 101 that may be would start with some panel discussion of the various roles that models can play.”
1 | “Training will be useful but the need can vary greatly from EPC to EPC.”