# Revised Discussion Guide

1. What problems, research questions, or situations are most appropriate for the development and inclusion of decision models and/or simulation?
2. What model outputs (types and forms) deliver the greatest utility to the stakeholders (Policymakers, Patients, Providers)?
3. What is your working definition of a model? How do you distinguish it from other analytical techniques? How do you distinguish it from other forms of evidence? How do you evaluate model-based evidence from other empirical evidence?
4. How do you evaluate a model? How do you determine the “value” of a model and the evidence it provides?