# Semistructured Interview Guide

We interviewed EPC directors (and relevant staff) about lessons learned from incorporating, [underlined: or not] incorporating, models in EPC reports.

a. Has considered and attempted to incorporate modeling but decided not to complete such a task
b. Has not considered developing or incorporating models at all.

## Key Themes

For all EPC members, we asked the following questions.

- Familiarity with models
  ○ Shared language set – how EPCs understand modeling terms
- Interest
- Access to modeling resources/expertise
- Usefulness
- Use of models
- Use of evidence generated by models (from others) as part of the systematic review
- How to recognize value/need for model at inception
- Impact on systematic review planning, timeline, budget
  ○ How would these differ for different EPC mandates, i.e., OMAR, CER, generalist topics, USPSTF-related projects
- Resources needed
  ○ Should modeling teams work separately from review team?
- Should training be offered?
- Impact of evidence generated by models on patients
- Impact of evidence generated by models on providers
- Impact of evidence generated by models on policymakers

For all EPC members who had experience with using models, we asked the following questions.

- Specifics on:
  ○ What, how, who – details of the model and modeling process
  ○ Effort, resources used
  ○ How to recognize value/need for model at inception
  ○ Impact on systematic review planning, timeline, budget
  ○ Training
- Are you [underlined: familiar] with employing decision and/or simulation modeling techniques to augment scope/use of evidence? How much?
- Are you [underlined: interested] in employing decision and/or simulation modeling to estimate outcomes when there is insufficient evidence to explicitly answer pressing policy needs? Why or why not?
- In your EPC work, have you [underlined: used] or [underlined: attempted to use] decision and/or simulation modeling to estimate outcomes when there is insufficient evidence to explicitly answer pressing policy needs? Why or why not?
- Have you reviewed models and their output for inclusion in systematic reviews? Have you included such information as part of the evidence? How do you “treat,” weigh, and present that evidence in the reviews?
  [underlined: If YES:]
  - What were the opportunities?
  - What role did you play in the modeling effort?
  - Who else was involved, and what were their roles?
  - How well did it work?
  - What were your expectations? Were they met? Why or why not?
  - What were the main challenges?
  - Would you say the modeling activities were successful? Why or why not? How do you define “success” in this context?
  - Why did it work/fail?
  - How much effort was expended overall?
  - How much effort was expended relative to the total effort for this project (systematic reviews, etc.)?
  - How did modeling affect your planning for a systematic review? Timelines? Budget?
  - Did you incorporate the model in final report/recommendation? Why or why not?
  - How did you proceed?
  - Did you use other experts/resources to assist you? Who? How did you find assistance? How did you decide on who/what you needed?
  - Did you examine alternative modeling techniques? Which ones? If not, why not?
  - How did you/the team decide on the modeling approach?
  - What factors influenced the modeling approach?
  - Describe modeling activities from model formulation (including assumptions) to model development, testing, validation, and implementation. Comment on facilitators/barriers for each step.
  - What kind of models did you use?
  - Would you recommend to others to use similar strategies? Why or why not?
  - Would you try again in future projects? Why or why not?
  - If so, would you do anything differently? What? Why or why not?
  - How often do you think you can recognize the value/need for modeling at the inception of a review?
  - How do you recognize value/need?
  - Can you anticipate the need for modeling? How?
  - Should EPCs be offered training in modeling?
- Do you have [underlined: access] to necessary resources to develop, analyze, and implement decision and/or simulation models? Which ones?
- Do you believe decision and/or simulation modeling can be [underlined: useful] to augment evidence to explicitly answer pressing policy needs? Why or why not?
- Do you believe decision and/or simulation modeling to estimate outcomes can be successfully [underlined: used] to augment evidence to explicitly answer pressing policy needs? Why or why not?
- Do you think [underlined: patients] can rely on evidence (partly) based on decision and/or simulation modeling? Why or why not? How should such reports be developed/presented so as to gain trust/acceptance by patients?
- Do you think [underlined: providers] can rely on evidence (partly) based on decision and/or simulation modeling? Why or why not? How should such reports be developed/presented so as to gain trust/acceptance by providers?
- Do you think [underlined: policymakers] can rely on evidence (partly) based on decision and/or simulation modeling? Why or why not? How should such reports be developed/presented so as to gain trust/acceptance by policy makers?
- How does modeling fit with the goals of stakeholders/partners?
- Have you reviewed models and their output for inclusion in systematic reviews? Have you included such information as part of the evidence? How do you “treat,” weigh, and present that evidence in the reviews?
  [underlined: If NO]:
  - Have you read/seen reports/publications detailing the use of decision and/or simulation modeling alongside scientific reviews of evidence? If so, what is your impression/reaction to such approach?
  - How often do you think you can recognize the value/need for modeling at the inception of a review?
  - How do you recognize value/need?
  - Should EPCs be offered training in modeling?
  - Would you try modeling in future projects? Why or why not?
  - If so, how would you approach such effort?
  - How would modeling affect your planning for a systematic review? Timelines? Budget?
  - What challenges would you anticipate? How would you address them?
  - What do you think you would need? Do you know how to access such resources?
- Do you have [underlined: access] to necessary resources to develop, analyze, and implement decision and/or simulation models? Which ones?
- Do you believe decision and/or simulation modeling can be [underlined: useful] to augment evidence to explicitly answer pressing policy needs? Why or why not?
- Do you believe decision and/or simulation modeling to estimate outcomes can be successfully [underlined: used] to augment evidence to explicitly answer pressing policy needs? Why or why not?
- Do you think [underlined: patients] can rely on evidence (partly) based on decision and/or simulation modeling? Why or why not? How should such reports be developed/presented so as to gain trust/acceptance by patients?
- Do you think [underlined: providers] can rely on evidence (partly) based on decision and/or simulation modeling? Why or why not? How should such reports be developed/presented so as to gain trust/acceptance by providers?
- Do you think [underlined: policymakers] can rely on evidence (partly) based on decision and/or simulation modeling? Why or why not? How should such reports be developed/presented so as to gain trust/acceptance by policy makers?
- How does modeling fit with the goals of stakeholders/partners?