# Search String and Results

1 decision analytic model$.mp. [mp=title, original title, abstract, name of substance word, subject heading word, unique identifier] | 683
2 decision analys$.mp. [mp=title, original title, abstract, name of substance word, subject heading word, unique identifier] | 2,755
3 simulation model$.mp. [mp=title, original title, abstract, name of substance word, subject heading word, unique identifier] | 3,519
4 markov model$.mp. [mp=title, original title, abstract, name of substance word, subject heading word, unique identifier] | 3,184
5 state transition model$.mp. [mp=title, original title, abstract, name of substanceword, subject heading word, unique identifier] | 152
6 markov cohort model.mp. [mp=title, original title, abstract, name of substance word, subject heading word, unique identifier] | 12
7 or/3 | 6 6,817
8 QALY.mp. [mp=title, original title, abstract, name of substance word, subject heading word, unique identifier] | 2,108
9 quality adjusted li$.mp. [mp=title, original title, abstract, name of substance word, subject heading word, unique identifier] | 5,617
10 quality adjusted life.mp. [mp=title, original title, abstract, name of substance word, subject heading word, unique identifier] | 5,613
11 quality adjusted days.mp. [mp=title, original title, abstract, name of substance word, subject heading word, unique identifier] | 23
12 quality adjusted month$.mp. [mp=title, original title, abstract, name of substance word, subject heading word, unique identifier] | 13
13 quality adjusted survival.mp. [mp=title, original title, abstract, name of substance word, subject heading word, unique identifier] | 212
14 quality adjusted year$.mp. [mp=title, original title, abstract, name of substance word, subject heading word, unique identifier] | 66
15 or/8 | 14 5,908
16 ICER.mp. [mp=title, original title, abstract, name of substance word, subject heading word, unique identifier] | 677
17 (incremental adj2 ratio).mp. [mp=title, original title, abstract, name of substance word, subject heading word, unique identifier] | 78
18 (incremental adj3 ratio).mp. [mp=title, original title, abstract, name of substance word, subject heading word, unique identifier] | 1,221
19 or/16-18 Advanced Display | 1,565
20 DALY.mp. [mp=title, original title, abstract, name of substance word, subject heading word, unique identifier] | 406
21 disability adjusted life year$.mp. [mp=title, original title, abstract, name of substance word, subject heading word, unique identifier] | 572
22 20 or 21 | 733
23 monte carlo.mp. [mp=title, original title, abstract, name of substance word, subject heading word, unique identifier] | 17,762
24 decision tree.mp. [mp=title, original title, abstract, name of substance word, subject heading word, unique identifier] | 1,995
25 microsimulation.mp. [mp=title, original title, abstract, name of substance word, subject heading word, unique identifier] | 185
26 15 or 19 or 22 or 23 or 24 or 25 | 26,611
27 7 and 26 | 1,441
28 cost utility.mp. [mp=title, original title, abstract, name of substance word, subject heading word, unique identifier] | 1,432
29 cost effective $.mp. [mp=title, original title, abstract, name of substance word, subject heading word, unique identifier] | 48,974
30 28 or 29 | 49,475
31 limit 30 to (clinical trial, all or clinical trial, phase i or clinical trial, phase ii or clinical trial, phase iii or clinical trial, phase iv or clinical trial or controlled clinical trial or randomized controlled trial) | 4,817
32 30 not 31 | 44,658
33 32 and 26 | 4,135
34 1 or 2 or 27 or 33 | 7,361
35 limit 34 to (English language and humans) | 6,525
36 exp Environment/ | 682,103
37 exp Environmental Illness/ or exp Environmental Exposure/ or exp Environmental Pollution/ or exp Environmental Medicine/ or exp Environmental Monitoring/ or exp Environmental Pollutants/ or exp Environmental Health/ | 356,251
38 36 or 37 | 936,163
39 35 not 38 | 6,396
40 limit 39 to yr=”2009“ (before duplicates) | 562
41 limit 39 to yr=”2008“ (before duplicates) | 615
42 limit 39 to yr=”2007“ (before duplicates) | 576
43 limit 39 to yr=”2006“ (before duplicates) | 525
44 limit 39 to yr=”2005“ (before duplicates) | 481