# Acronyms/Abbreviations

AHRQ: Agency for Healthcare Research and Quality
CISNET: Cancer Intervention and Surveillance Modeling Network
COMNet: Collaborative Obesity Modeling Network
EPC: Evidence-based practice center
EVCI: Expected value of clinical information
IOM: Institute of Medicine
LY: Life years
MeSH: Medical subject headings
NIH: National Institutes of Health
QALY: Quality-adjusted life years
TEP: Technical Expert Panel
TOO: Task Order Officer
USPSTF: United States Preventive Services Task Force