# Results

## Aim 1 In a Representative Sample of Trials, Describe the Range of Correlation Values, r

All 127 studies with 281 total study groups that met criteria were included and data extracted (see Appendix C for the list of studies). From each study we extracted an average of 3.0 outcomes. Thus, in total we calculated 852 values of r, of which 811 (95%) values from 123 studies were valid estimates of the correlation coefficient (i.e., between -1 and 1) and are analyzed further. Only two studies (with 12 r values) were nonrandomized, so we did not further analyze study design. No study reported r values.

Given our sources of studies, kidney disease was an over-represented clinical domain: 38 studies (30%) evaluated kidney disease; 18 (14%) cardiology; 11 (9%) each diabetology and pulmonology; 8 (6%) gastroenterology; 6 (5%) hypertension; 5 (4%) each internal medicine and ophthalmology, 4 (3%) each genetic disorders and psychiatry; and 3 or fewer each 13 other clinical domains (see Table 2). The percentages of analyzed r values by clinical domain were similar, except that cardiology represented 18 percent of r values but only 14 percent of studies. About half the studies (66, 52%) were found in the clinicaltrials.gov database; the rest were from published trials included in previous systematic reviews we have conducted.

Table 2 Descriptive characteristics of included studies

Characteristic | Results
Number of studies | 123^*^
Number of groups analyzed | 811^*^
Median group sample size (25^th^, 75^th^ percentile) | 69 (23, 169)
Treatment type
Active treatment groups, n (%) | 611 (75%)
Median active treatment group sample size (25^th^, 75^th^ percentile) | 76 (23, 177)
Number of inactive (no) treatment groups, n (%) | 200 (25%)
Median inactive (no) treatment group sample size (25^th^, 75^th^ percentile) | 58 (24, 151)
Clinical domain † | n (% studies) [% values]
Kidney disease | 38 (30%) [31%]
Cardiology | 18 (14%) [18%]
Diabetology | 11 (9%) [9%]
Pulmonology | 11 (9%) [9%]
Gastroenterology | 8 (6%) [5%]
Hypertension | 6 (5%) [5%]
Internal Medicine | 5 (4%) [5%]
Ophthalmology | 5 (4%) [3%]
Genetic disorders | 4 (3%) [2%]
Psychiatry | 4 (3%) [4%]
Critical care | 3 (2%) [2%]
Pediatrics | 3 (2%) [3%]
Rheumatology | 3 (2%) [1%]
Dermatology | 2 (2%) [0.7%]
Immunology | 2 (2%) [0.5%]
Urology | 2 (2%) [2%]
Geriatrics | 1 (1%) [2%]
Gynecology | 1 (1%) [1%]
Infectious diseases | 1 (1%) [0.2%]
Neonatology | 1 (1%) [0.2%]
Neurology | 1 (1%) [0.7%]
Orthopedics | 1 (1%) [0.2%]
Transplant | 1 (1%) [0.5%]
Outcome type | n (% studies) [% values]
Device measures | 32 (26%) [15%]
Laboratory values | 61 (50%) [39%]
Other | 10 (8%) [3%]
Questionnaires/Scores | 42 (34%) [23%]
Signs | 36 (29%) [16%]
Symptoms | 7 (6%) [3%]
Followup duration, in months
All groups, median (25^th^, 75^th^ percentile) | 3 (1.4, 7.35)
Active treatment, median (25^th^, 75^th^ percentile) | 3.7 (1.4, 12.2)
Placebo, median (25^th^, 75^th^ percentile) | 2.8 (0.7, 5.6)

* 41 study groups were excluded because the statistics reported resulted in impossible correlation values (lower than -1 or higher than +1), presumably due to rounding or reporting error. After these exclusions 4 of the 127 studies contributed no study groups to the analyses.

† Including double counting where 1 study was categorized with 3 conditions and 3 studies were categorized with 2 conditions each.

n = number of study groups (separately derived r values).

The most common outcome type was laboratory measures (39%), followed by questionnaires or scores (23%), signs (16%), device measures (15%), and symptoms (3%), and other types (3%)—including medication use and physical tests. There were 611 values from active treatment groups and 200 from placebo/no treatment/usual care groups; the apparent disparity occurred because most studies compared two or more active treatments.

Within-group baseline sample sizes ranged from 2 to 6,264 with a median (interquartile range [IQR]) of 69 (23, 169) participants. The median (IQR) analyzed duration of followup was 3 (1.4, 7.35) months with a range of 0.5 hours to 4.9 years.

### Estimated Correlation Values

The vast majority of estimated correlation values were positive (Figure 1 and Table 3); the median (IQR) within-group correlation value across all studies was 0.59 (0.40, 0.81). For active treatment groups, correlation values had a median of 0.54 (0.37, 0.77) and for no treatment groups 0.73 (0.53, 0.87); P<0.001. Negative correlation values were uncommon (4.1%). The distributions of correlation values were heterogeneous (P<0.001) across both outcome types (Figure 2) and clinical domains (Figure 3).

Figure 1 Histograms of the estimated correlation values across study groups

This figure displays three histograms, each showing the percent of estimates in categories of estimated correlations (ranging from -1 to 1); the estimated correlation categories have a width of 0.05. Separate histograms are displayed for “all groups”, “placebo” groups, and “active treatment” groups. The histograms all show rare occurrences (<1%) for estimated correlations below 0. For “all groups”, there is an increasing occurrence of estimated correlation values from 0 to approximately 0.5, above which the occurrence is fairly stable between approximately 7% and 9% of study groups. For “placebo” groups, there is a steady rise in the percentage of estimates from correlation values of 0 up to the peak value of 0.95, with approximately 15% of study groups. The “active treatment” groups histogram is fairly similar to the “all groups” histogram, though with correlation categories between 0.45 and 0.55 with about 9% to 10% of groups and correlation categories of 0.6 to 1.0 with about 6% to 8% of groups.

Table 3 Within-group estimated correlation values by group characteristics

Group Characteristic | Median | 25^th^, 75^th^ Percentile | Min, Max | Comparison Between Groups
All groups | 0.59 | 0.40, 0.81 | -1.00, 1.00 | NA
Active treatment | 0.54 | 0.37, 0.77 | -1.00, 1.00 | P<0.001
Inactive (no) treatment | 0.73 | 0.53, 0.87 | -0.03, 1.00 | P<0.001
Outcome types
Device measure | 0.83 | 0.61, 0.94 | -0.42, 1.00 | P<0.001
Lab | 0.63 | 0.39, 0.81 | -0.94, 1.00 | P<0.001
Sign | 0.51 | 0.37, 0.72 | -0.77, 1.00 | P<0.001
Questionnaire/Score | 0.51 | 0.34, 0.68 | -1.00, 1.00 | P<0.001
Symptoms | 0.44 | 0.38, 0.50 | -0.07, 0.82 | P<0.001
Other | 0.78 | 0.71, 0.87 | 0.38, 1.00 | P<0.001
Clinical domains
Nephrology | 0.61 | 0.44, 0.82 | -0.88, 1.00 | P<0.001
Cardiovascular medicine | 0.59 | 0.35, 0.86 | -0.94, 0.99 | P<0.001
Pulmonary medicine | 0.77 | 0.54, 0.94 | -1.00, 1.00 | P<0.001
Diabetology | 0.65 | 0.44, 0.76 | -0.17, 0.93 | P<0.001
Internal medicine/Geriatrics/Primary care | 0.73 | 0.56, 0.83 | 0.25, 0.91 | P<0.001
Gastroenterology/Hepatology | 0.44 | 0.23, 0.55 | -0.38, 0.99 | P<0.001
Psychiatry | 0.36 | 0.22, 0.58 | 0.14, 1.00 | P<0.001
Neonatology/Pediatrics | 0.6 | 0.46, 0.84 | 0.23, 0.94 | P<0.001
Ophthalmology | 0.38 | 0.26, 0.54 | -0.42, 0.69 | P<0.001
Critical care | 0.56 | 0.38, 0.70 | -0.07, 0.84 | P<0.001
Others | 0.52 | 0.34, 0.77 | -0.19, 1.00 | P<0.001

Max = maximum; Min = minimum; NA = not applicable P-values from the Kruskall-Wallis test

Figure 2 Box plot of estimated correlation values by outcome type

Within each box, horizontal white lines denote median values; boxes extend from the 25^th^ to the 75^th^ percentile of each group's distribution of values; vertical extending lines denote adjacent values (i.e., the most extreme values within 1.5 interquartile range of the 25^th^ and 75^th^ percentile of each group); dots denote observations outside the range of adjacent values.

This figure displays box plots for study groups categorized by outcomes. The figure visually replicates the data in Table 3, under “Outcome types”.

Figure 3 Box plot of estimated correlation values by clinical domain

Within each box, horizontal white lines denote median values; boxes extend from the 25^th^ to the 75^th^ percentile of each group's distribution of values; vertical extending lines denote adjacent values (i.e., the most extreme values within 1.5 interquartile range of the 25^th^ and 75^th^ percentile of each group); dots denote observations outside the range of adjacent values.

CRIT = critical care CVD = cardiovascular disease; DM = diabetes mellitus; GI/HEP = gastroenterology, hepatology; IM/GER/PRIM = internal medicine, geriatrics, primary care; NEO/PEDS = neonatology, pediatrics; NEPH = nephrology; OPHTH = ophthalmology; PSYCH = psychiatry; PULM = pulmonology

This figure displays box plots for study groups categorized by clinical domains. The figure visually replicates the data in Table 3, under “Clinical domains”.

As shown in Figure 4, the estimated correlation did not appear to be associated with increasing followup duration (Spearman rho = -0.07; P=0.054); this was true both among active treatment (rho=-0.03; P=0.53) and no treatment groups (rho = -0.05; P=0.46). As shown in Figure 5, correlation values were lower with increasing baseline sample size (rho = -0.09; P=0.017). This effect was present among no treatment groups (rho = -0.25; P<0.001), but apparently not among active treatment groups (rho = -0.02; P=0.70).

Figure 4 Scatter plot of estimated correlation values by study duration (square root transformed)

mo = month; yr = year

Red lines are locally weighted smoothing lines (LOWESS).

This figure displays three scatter plots, each comparing estimated correlation (on the y axis) and duration of followup (on the x axis, on a square root scale) ranging from 1 day to 5 years. Separate histograms are displayed for “all groups”, “placebo/no treatment” groups, and “active treatment” groups. Locally weighted smoothing lines (LOWESS) are drawn. The scatter plots display that the large majority of study groups had followup durations of 1 year or less. For all groups, the LOWESS line shows decreasing correlation values from about 0.75 at <1 day to about 0.5 at approximately 1 month, steady estimates (at 0.5) to about 1.5 years, then decreasing correlation values to about 0.25 at 5 years. For placebo groups, the LOWESS is fairly flat across duration (to a maximum of 2 years), ranging from about 0.6 to 0.75. For active treatment groups, the LOWESS line is similar to the all groups line.

Figure 5 Scatter plot of estimated correlation values by baseline sample size (ln-transformed)

Red lines are locally weighted smoothing lines (LOWESS).

This figure displays three scatter plots, each comparing estimated correlation (on the y axis) and sample size (on the x axis, on a log scale) ranging from 1 to 10,000. Separate histograms are displayed for “all groups”, “placebo/no treatment” groups, and “active treatment” groups. Locally weighted smoothing lines (LOWESS) are drawn. The scatter plots display that the large majority of study groups had samples sizes between about 25 and 500. In all three scatter plots the LOWESS lines are fairly flat (at approximately 0.5) between sample sizes of about 10 to 500. The all groups and active treatment scatter plots display mostly lower correlation values where there are few data points below and above the range of about 10 to 500.

To explore the association of the correlation coefficient with study or group-level characteristics we used a multivariable linear mixed effects model. The model identified a statistically significant effect of treatment type on the estimated correlation coefficient (correlation values were lower by 0.18 in active treatment versus placebo/no treatment groups; P<0.001), after adjusting for baseline sample size, medical field, study duration, and outcome measure type, while accounting for clustering of treatment groups within studies. Inclusion of a cross-product term between study duration and treatment type did not reveal statistically significant effect modification (P=0.60), indicating that there is no differential effect of study duration on r values by treatment type. However, inclusion of a product term between baseline sample size and treatment type demonstrated statistically significant effect modification (P=0.007), suggesting that larger baseline sample size was more strongly associated with lower correlation coefficient values in placebo/no treatment groups, compared with active treatment groups.

## Aim 2 In a Representative Sample of Trials, Compare Values of the Net-Change SEs Derived From Reported Within-Group SEs, With the Net-Change SEs Derived From Estimating the Correlation Values, r

Figure 6 compares the reported within-group standard errors (SEs) for each study group versus SEs calculated using different imputed values (ρ=0, 0.25, 0.50, and 0.75). Imputing a value of 0 (i.e., lower than the majority of within-group correlations) leads to overestimation of the within-group SEs in the majority of cases (95% overall; 50% by more than 1.5 times). Similarly, when a value of 0.25 is imputed the SE of the net change is overestimated in the majority of cases (87% overall), however the magnitude of underestimation is smaller (39% by more than 1.5 times). When a value of 0.5 is imputed (i.e., a value close to the median of the empirical distribution of within-group correlation values) 62 percent of the SEs are overestimated and 38 percent are underestimated.^d^ Finally, when a value of 0.75 is imputed the majority of net-change SEs are underestimated (68%).

d Recall that a value of 0.59 will result in 50% of the within-group SEs to be overestimated and 50% to be underestimated.

Figure 6 Comparison between reported standard errors for within-group changes and standardized bias of imputed versus reported standard errors with different values of imputed r

SE = standard error; SE_imputed_ = standard error for the within-group change calculated using imputed correlation values; SE_reported_ = standard error for the within group change as reported in the studies

Dashed horizontal lines indicate the line of no difference between reported and calculated (after imputation) standard errors.

Extreme values (>20 on the x-axis and >2 on the y-axis) have been suppressed to avoid distortion of the graph.

This figure displays four scatter plots comparing the reported within-group change standard errors (on the x axis) and the standardized bias of the standard error, calculated as (imputed SE minus reported SE) divided by reported SE (on the y axis). The four scatter plots display the four scenarios of r=0, 0.25, 0.50, and 0.75. If r=0, almost all imputed standard errors are larger than the reported standard errors, with the majority between about 10% and 100% larger. The scatter plot for r=0.25 is similar to where r=0, but shifted downward such that the majority of imputed standard errors are between about 10% smaller to about 90% larger than the reported standard errors. When r=0.50, the bias of imputed standard errors is shifted further down and the mode of the biases is about 0. When r=0.75, the bias is shifted further down and the majority of standard errors are about 10% to 50% smaller than reported standard errors.

Figure 7 compares the net-change SEs calculated using complete data versus those calculated using different imputed values for the within-group correlation (the same value was imputed for both groups being compared). The figure shows that when the imputed value is 0 (i.e., lower than the majority of within-group correlations) the SE of the net-change is overestimated in the majority of cases (97% overall; 78% by more than 1.5 times). Similarly, when a value of 0.25 is imputed the SE of the net change is underestimated in the majority of cases (94% overall), however the magnitude of overestimation is smaller (73% by more than 1.5 times). When values of 0.5 or 0.75 were imputed (i.e., close or higher than the median of the empirical distribution of within-group correlation values), SEs were still likely to be overestimated (83% and 70%, respectively).^e^

e Recall that we arbitrarily selected pairs of groups from each study and that some studies contributed several groups to analyses of within-group change. Therefore, use of the median of the overall distribution of correlation values is not guaranteed to “balance” underestimation and overestimation in the net change analyses).

Figure 7 Comparison between net-change standard errors calculated using complete data and standardized bias of net-change standard errors calculated using imputed versus reported within-group correlation values with different values of imputed r

SE_imputed_ = standard error for the net-change calculated using within-group standards based on imputed values; SE_reported_ = standard error for the net-change calculated using the within-group standard errors as reported in the studies

Dashed horizontal lines indicate the line of no difference between net-change standard errors based on the complete data and those based on imputed values. Extreme values (>20 on the x-axis and >2 on the y-axis) have been suppressed to avoid distortion of the graph.

This figure displays four scatter plots comparing the net change standard errors calculated from reported standard errors (on the x axis) and the standardized bias of the net change standard error, calculated as (imputed net change SE minus reported net change SE) divided by reported net change SE (on the y axis). The four scatter plots display the four scenarios of r=0, 0.25, 0.50, and 0.75. The distribution of reported and imputed standard errors are very similar to those in Figure 6.

## Aim 3 By Simulation, Explore the Impact of Imputing a Range of Correlation Values, r, on Fixed and Random Effects Model Meta-Analyses

Here, we present results from simulations of random effects meta-analyses with 10 studies for all magnitudes of the treatment effect (0, 0.1, 0.5, or 1), under homogeneity and different levels of heterogeneity (τ^2^=0, 0.1, or 0.5), for all control group sample sizes (n=20, 50, or 100), and for different within-group correlation parameter values (ρ=0, 0.40, 0.59, or 0.81). Across these scenarios, when data on the correlation were not missing, the simulation error ranged between 0.0010 and 0.0127 for meta-analyses with 5 studies; between 0.0007 and 0.0087 for meta-analyses with 10 studies; and between 0.0005 and 0.0062 for meta-analyses with 20 studies. We restrict the presented results to cases where the sample size of the treatment and control groups were equal, and the baseline and final measurement variances in the treatment group were also equal. The following alternative scenarios produced very similar results and are presented in Appendix B: unequal treatment group variances, imbalanced treatment and control group sample size, smaller (5 studies) and larger (20 studies) meta-analyses, and using a fixed effect inverse variance meta-analysis method. Similarly, results from fixed effects analyses are only presented in Appendix B. In these analyses the impact of imputing correlation values was qualitatively similar to that in random effect analyses. However, we note that coverage probabilities were generally very poor in the presence of heterogeneity.

We first present detailed results for meta-analyses where missing correlation values are imputed with a value of r=0.5, because this represents a standard approach in applied meta-analyses. We then assess the impact of imputation of a broad range of values, under different values of the correlation parameter.

### Imputing a Correlation Value of 0.5

Figures 8 to 11 show the average bias (across 1,000 simulations) for four different values of the correlation parameter (r=0, 0.40, 0.59, and 0.81). Each figure shows results for three imputation scenarios: (1) complete reporting of data (hollow circles), (2) incomplete data (hollow squares), and (3) partially complete data (hollow triangles). In each figure, results are presented for three heterogeneity levels (τ^2^=0, 0.1, or 0.5; one scenario per row), three sample sizes (20, 50, or 100 patients per randomized group; one scenario per column), and four magnitudes of the treatment effect (0, 0.1, 0.5, and 1; within each panel).

Figure 8 Average bias across 1,000 simulated meta-analyses under various scenarios (ρ=0)

SS = Sample size; SSR = sample size ratio; VR = variance ratio; ρ = correlation parameter value; τ^2^ = between-study variances of the treatment effect

○ = meta-analyses where within-group correlations were reported from all studies; △ = meta-analyses where 50% of the within-group correlations were missing; □ = meta-analyses where all within-group correlations were missing

Horizontal dashed lines denote the absence of bias

Nine subplots are displayed with treatment effect (ranging from 0 to 1) on the x axis and bias (ranging from -0.1 to 0.1) on the y axis. Each subplot displays the different scenarios where τ2 = 0, 0.1, or 0.5, and where sample size = 20, 50, or 100. Within each plot the simulated meta-analyses under three scenarios (within-group correlations were reported from all studies, 50% of the within-group correlations were missing, and all within-group correlations were missing) at four different treatment effects (0, 0.1, 0.5, and 1). In all scenarios the simulated meta-analyses with different percentages of missing correlations were nearly identical. Also, all scenarios show no or very small bias (less than about 0.01).

Figure 9 Average bias across 1,000 simulated meta-analyses under various scenarios (ρ=0.40)

SS = sample size; SSR = sample size ratio; VR = variance ratio; ρ = correlation parameter value; τ^2^= between-study variance of the treatment effect

○ = meta-analyses where within-group correlations were reported from all studies; △ = meta-analyses where 50% of the within-group correlations were missing; □ = meta-analyses where all within-group correlations were missing

Horizontal dashed lines denote the absence of bias

The same nine subplots are displayed as in Figure 8. In all scenarios the simulated meta-analyses with different percentages of missing correlations were nearly identical. Also, all scenarios show no or very small bias (less than about 0.01).

Figure 10 Average bias across 1,000 simulated meta-analyses under various scenarios (ρ=0.59)

SS = sample size; SSR = sample size ratio; VR = variance ratio; ρ = correlation parameter value; τ^2^= between-study variance of the treatment effect

○ = meta-analyses where within-group correlations were reported from all studies; △ = meta-analyses where 50% of the within-group correlations were missing; □ = meta-analyses where all within-group correlations were missing

Horizontal dashed lines denote the absence of bias

The same nine subplots are displayed as in Figure 8. In all scenarios the simulated meta-analyses with different percentages of missing correlations were nearly identical. Also, all scenarios show no or very small bias (less than about 0.01).

Figure 11 Average bias across 1,000 simulated meta-analyses under various scenarios (ρ=0.81)

SS = sample size; SSR = sample size ratio; VR = variance ratio; ρ = correlation parameter value; τ^2^ = between-study variance of the treatment effect

○ = meta-analyses where within-group correlations were reported from all studies; △ = meta-analyses where 50% of the within-group correlations were missing; □ = meta-analyses where all within-group correlations were missing

Horizontal dashed lines denote the absence of bias

The same nine subplots are displayed as in Figure 8. In all scenarios the simulated meta-analyses with different percentages of missing correlations were nearly identical. Also, all scenarios show no or very small bias (less than about 0.01).

Null correlation parameter (ρ=0). This set of scenarios represents an extreme case where the imputed value (r=0.5) was substantially larger compared with the parameter value (ρ=0). The value of biases in all scenarios was close to zero (Figure 8). Notably, there were no differences across different scenarios with 0, 50, and 100 percent of studies requiring imputation of r.

25^th^percentile correlation parameter (ρ=0.40). This set of scenarios where the imputed correlation value (r=0.5) is closer to the parameter value (ρ=0.40) also demonstrates that there is no bias in the estimation of the treatment effect introduced by imputing missing within-group correlation values, regardless of extent of heterogeneity, magnitude of the treatment effect, or study sample size (Figure 9). The results are nearly identical when all studies report complete data, or when 50 or 100 percent of studies do not report correlation values.

50^th^ percentile correlation parameter (ρ=0.59). Similar to the preceding scenario, using an imputed value of r=0.5 when the parameter value ρ=0.59 does not introduce bias in the meta-analytic estimate of the treatment effect (Figure 10).

75^th^percentile correlation parameter (ρ=0.81). In scenarios where the imputed correlation value (r=0.5) is substantially lower than the parameter value (ρ=0.81), imputation of missing correlation values does not introduce bias in the estimate of the treatment effect (Figure 11).

Coverage.Figures 12–15 show the observed coverage probabilities (across 1,000 simulations) for four different values of the correlation parameter (ρ=0, 0.40, 0.59, and 0.81). The figures are structured in the same way as the bias figures, presenting the same scenarios. The desired coverage probability is 0.95, corresponding with the 95 percent confidence interval. Imputing correlation values appeared to have a substantial effect on the coverage probabilities in several of the simulated scenarios.

Figure 12 Coverage probabilities across 1,000 simulated meta-analyses under various scenarios (ρ=0)

SS = sample size; SSR = sample size ratio; VR = variance ratio; ρ = correlation parameter value; τ^2^ = between-study variance of the treatment effect

○ = meta-analyses where within-group correlations were reported from all studies; △ = meta-analyses where 50% of the within-group correlations were missing; □ = meta-analyses where all within-group correlations were missing

Horizontal dashed lines denote the nominal coverage probability of the estimator

The same nine subplots are displayed as in Figure 8, except that the y axis displays coverage probability ranging from 0.85 to 1, where nominal coverage is 0.95. In all scenarios the coverage probabilities when all within-group correlations were missing are lower than when 50% of correlations are missing, which in turn are lower than when all correlations were reported (no imputation of correlation was needed). The figures are best described in the text on page 20 under “Null correlation parameter (ρ=0)”.

Figure 13 Coverage probabilities across 1,000 simulated meta-analyses under various scenarios (ρ=0.40)

SS = sample size; SSR = sample size ratio; VR = variance ratio; ρ = correlation parameter value; τ^2^ = between-study variance of the treatment effect

○ = meta-analyses where within-group correlations were reported from all studies; △ = meta-analyses where 50% of the within-group correlations were missing; □ = meta-analyses where all within-group correlations were missing

Horizontal dashed lines denote the nominal coverage probability of the estimator

The same nine subplots are displayed as in Figure 12. In all scenarios the coverage probabilities when all within-group correlations were missing are lower than when 50% of correlations are missing, which in turn are lower than when all correlations were reported (no imputation of correlation was needed). The figures are best described in the text on page 21 under “25th percentile correlation parameter (ρ = 0.40)”.

Figure 14 Coverage probabilities across 1,000 simulated meta-analyses under various scenarios (ρ=0.59)

SS = sample size; SSR = sample size ratio; VR = variance ratio; ρ = correlation parameter value; τ^2^ = between-study variance of the treatment effect

○ = meta-analyses where within-group correlations were reported from all studies; △ = meta-analyses where 50% of the within-group correlations were missing; □ = meta-analyses where all within-group correlations were missing

Horizontal dashed lines denote the nominal coverage probability of the estimator

The same nine subplots are displayed as in Figure 12. In all scenarios the coverage probabilities when all within-group correlations were missing are lower than when 50% of correlations are missing, which in turn are lower than when all correlations were reported (no imputation of correlation was needed). The figures are best described in the text on pages 22-23 under “50th percentile correlation parameter (ρ = 0.59)”.

Figure 15 Coverage probabilities across 1,000 simulated meta-analyses under various scenarios (ρ=0.81)

SS = sample size; SSR = sample size ratio; VR = variance ratio; ρ = correlation parameter value; τ^2^ = between-study variance of the treatment effect

○ = meta-analyses where within-group correlations were reported from all studies; △ = meta-analyses where 50% of the within-group correlations were missing; □ = meta-analyses where all within-group correlations were missing

Horizontal dashed lines denote the nominal coverage probability of the estimator

The same nine subplots are displayed as in Figure 12. In all scenarios the coverage probabilities when all within-group correlations were missing are lower than when 50% of correlations are missing, which in turn are lower than when all correlations were reported (no imputation of correlation was needed). The figures are best described in the text on page 23 under “75th percentile correlation parameter (ρ = 0.81)”.

Null correlation parameter(ρ=0). Contrary to the observations regarding bias, imputing missing within-group correlation values substantially affected the observed coverage probabilities in these scenarios (Figure 12). Generally, coverage probabilities using imputed data (squares in figures) were lower compared with meta-analyses using complete data (circles in figure). Imputing correlation values (r=0.5) larger than the parameter value (ρ=0) underestimates the SE of the within-group change^f^, and consequently the SE of the net change^g^, resulting in spuriously narrow confidence intervals. Even in the absence of bias in the point estimate, narrower confidence intervals lead to lower coverage probabilities. Notably, in the presence of moderate (τ^2^=0.1) or severe (τ^2^=0.5) heterogeneity, coverage of the DerSimonian-Laird summary estimate was poor, regardless of whether studies reported complete data. The effect of the summary estimate's performance on coverage was substantially larger than the effect of imputation when τ^2^=0.5.

f Recall that for each treatment arm, SE_change within − arm_ = sqrt(SE_Final_^2^ + SE_Baseline_^2^ − 2 × r × SE_Final_ × SE_Baseline_)

g Recall that for treatments A and B, SE_NetChange_ = sqrt(SE_A_^2^ + SE_B_^2^) , where SE_A_ and SE_B_ are the standard errors of the within-arm change for arms A and B, respectively.

25^th^percentile correlation parameter (ρ=0.40). In these scenarios the imputed value (r=0.5) is closer to the true value (ρ=0.40). Thus, the impact of imputation on the study-specific SEs is smaller, leading to smaller differences in coverage probabilities between simulations with different percentages of studies requiring imputation (Figure 13). Different levels of coverage across the simulations with different degrees of heterogeneity reflect the poor performance of the DerSimonian-Laird estimate in the presence of substantial heterogeneity.

50^th^percentile correlation parameter (ρ=0.59). In these scenarios the imputed value is also very close to the true value (ρ=0.59), yielding similar results as the scenario above (Figure 14).

75^th^percentile correlation parameter (ρ=0.81). These scenarios represent cases where the imputed value (r=0.5) is substantially lower than the parameter value (ρ=0.81). Thus, the estimated study-specific SEs of the net change when imputing the within-group correlation is likely to be larger compared with those using the complete data (Figure 15). Thus, meta-analyses using imputed data will tend to produce wider confidence intervals and greater coverage compared with meta-analysis using complete data. In the absence of heterogeneity, imputation produced over-conservative coverage probabilities (higher than 0.95). In the presence of heterogeneity (τ^2^=0.1 or 0.5), imputation of correlation values lower than the parameter value appeared to partly “counteract” the lower-than-nominal coverage probabilities inherent in the DerSimonian-Laird estimate to some extent.

Mean square error (MSE). Figures 16 to 19 show the MSE (across 1,000 simulations) for four different values of the correlation parameter (ρ=0, 0.40, 0.59, and 0.81). The figures are structured in the same way as the bias figures, presenting the same scenarios. Generally, imputing some (50%) or all correlation values did not have an appreciable impact on the summary estimate's MSE. Furthermore, in all scenarios assessed it was clear that between-study heterogeneity and, to a smaller extent study sample size, were the key determinants of MSE.

Figure 16 Mean squared error across 1,000 simulated meta-analyses under various scenarios (ρ=0)

MSE = mean squared error; SS = sample size; SSR = sample size ratio; VR = variance ratio; ρ = correlation parameter value; τ^2^ = between-study variance of the treatment effect

○ = meta-analyses where within-group correlations were reported from all studies; △ = meta-analyses where 50% of the within-group correlations were missing; □ = meta-analyses where all within-group correlations were missing

The same nine subplots are displayed as in Figure 8, except that the y axis displays mean squared error ranging from 0 to 0.2. In all scenarios the simulated meta-analyses with different percentages of missing correlations were nearly identical. In all scenarios where τ2 = 0, the mean squared error was between 0 and about 0.02. In all scenarios where τ2 = 0.1, the mean squared error was about 0.25. In all scenarios where τ2 = 0.5, the mean squared error was between about 0.05 and 0.075, with somewhat higher values with smaller sample sizes.

Figure 17 Mean squared error across 1,000 simulated meta-analyses under various scenarios (ρ=0.40)

MSE = mean squared error; SS = sample size; SSR = sample size ratio; VR = variance ratio; ρ = correlation parameter value; τ^2^ = between-study variance of the treatment effect

○ = meta-analyses where within-group correlations were reported from all studies; △ = meta-analyses where 50% of the within-group correlations were missing; □ = meta-analyses where all within-group correlations were missing

The same nine subplots are displayed as in Figure 16. In all scenarios the simulated meta-analyses with different percentages of missing correlations were nearly identical. In all scenarios where τ2 = 0 or τ2 = 0.1, the mean squared error was between 0 and about 0.02. In all scenarios where τ2 = 0.5, the mean squared error was between about 0.04 and 0.06.

Figure 18 Mean squared error across 1,000 simulated meta-analyses under various scenarios (ρ=0.59)

MSE = mean squared error; SS = sample size; SSR = sample size ratio; VR = variance ratio; ρ = correlation parameter value; τ^2^ = between-study variance of the treatment effect

○ = meta-analyses where within-group correlations were reported from all studies; △ = meta-analyses where 50% of the within-group correlations were missing; □ = meta-analyses where all within-group correlations were missing

The same nine subplots are displayed as in Figure 16. In all scenarios the simulated meta-analyses with different percentages of missing correlations were nearly identical. In all scenarios where τ2 = 0 or τ2 = 0.1, the mean squared error was between 0 and about 0.02. In all scenarios where τ2 = 0.5, the mean squared error was between about 0.05 and 0.06.

Figure 19 Mean squared error across 1,000 simulated meta-analyses under various scenarios (ρ=0.81)

MSE = mean squared error; SS = sample size; SSR = sample size ratio; VR = variance ratio; ρ = correlation parameter value; τ^2^ = between-study variance of the treatment effect

○ = meta-analyses where within-group correlations were reported from all studies; △ = meta-analyses where 50% of the within-group correlations were missing; □ = meta-analyses where all within-group correlations were missing

The same nine subplots are displayed as in Figure 16. In all scenarios the simulated meta-analyses with different percentages of missing correlations were nearly identical. In all scenarios where τ2 = 0 or τ2 = 0.1, the mean squared error was between 0 and about 0.02. In all scenarios where τ2 = 0.5, the mean squared error was about 0.05.

All correlation parameters (ρ=0, 0.40, 0.59, and 0.81). The figures show that, regardless of the imputed correlation parameters, the imputation approach did not appreciably impact the MSE. Differences between scenarios where different percentages of available studies required imputation were much smaller in magnitude compared with the impact of between-study heterogeneity (across columns in the figure) and sample size (across rows).

### Imputing Alternative Correlation Values

To illustrate the impact of imputing alternative values when the within-group correlation is not reported, we use two illustrative simulation scenarios: one with no heterogeneity (τ^2^=0) and one with moderate heterogeneity (τ^2^=0.1). Both scenarios were based on meta-analyses of 10 studies, with 100 patients in the treatment and control groups, where the variance in the treatment group was not affected by treatment, over alternative values of the correlation parameter (ρ=0, 0.40, 0.59, or 0.81). For 1,000 meta-analyses simulated under these scenarios, we explored the impact of imputing correlation values ranging from -1 to 1, in steps of 0.10.

#### Bias

Consistent with the previously examined simulation scenarios, imputations of different values for the study-specific correlation when the information is missing from 50 or 100 percent of the included studies does not result in bias (average bias was 0 for all imputed values; data not shown).

#### Coverage Probabilities

Figure 20 presents the results for observed coverage probabilities across 1,000 simulated meta-analyses, when the nominal coverage level is 0.95. As expected, imputation of different correlation values had substantial impact on the coverage probabilities of the summary estimate. For all tested correlation parameter values (ρ=0, 0.40, 0.59, or 0.81), imputing larger values (closer to 1) reduced the coverage probability. In the case of no between-study heterogeneity (τ^2^=0), coverage probabilities were close to the nominal level (0.95) when the imputed value was close to the parameter value. When the imputed value was lower than the parameter value coverage was higher than nominal; the contrary was observed when the imputed value was larger than the parameter value (i.e. coverage was lower than the nominal level).

Figure 20 Coverage probabilities for alternative imputed correlation values for different values of the correlation parameter (meta-analysis of 5 studies)

This figure illustrates the impact of imputing alternative values when all studies in a meta-analysis do not report the within-group estimates of the correlation, for 4 different parameter values (ρ=0, 0.40, 0.59, and 0.81), under homogeneity (left panel) or heterogeneity (right panel) of treatment effects across studies. The horizontal red lines indicate the nominal coverage probability.

This figure illustrates the impact of imputing alternative values when all studies in a meta-analysis do not report the within-group estimates of the correlation, for 4 different parameter values (ρ= 0, 0.40, 0.59, or 0.81), under homogeneity (left panel) or heterogeneity (right panel) of treatment effects across studies. The subplots display the imputed correlation values on the x axis (ranging from -1 to 1) and coverage probability on the y axis (ranging from 0.8 to 1, where 0.95 is the nominal coverage probability). Each subplot shows points for coverage probability at imputed values at 0.1 intervals connected by unsmoothed lines, under four scenarios where τ2 = 0, 0.40, 0.59, and 0.81. The graphs are best described in the text on page 30, under “Coverage probabilities”.

In the presence of moderate heterogeneity (τ^2^=0.1) coverage probabilities were lower than nominal for all imputed and parameter values of the correlation. In these scenarios coverage was greater (and closer to nominal) when lower imputed values were used.

#### MSE

Consistent with the previously examined simulation scenarios, imputation of different values for the within-group correlation, does not appreciably affect MSE (data not shown).

## Summary of Key Findings

- In a large dataset of trials allowing the calculation of the within-arm correlation values, we found that estimated correlation values are positive in the vast majority of cases, regardless of the specific outcome measure and duration of followup.
  ○ Median (IQR) within-group correlation across studies 0.59 (0.40, 0.81).
  ○ Correlation values were statistically significantly higher for no treatment groups (median 0.73) than for active treatments (median 0.54; P<0.001).
  ○ Correlation values were statistically significantly different across different outcome types and different clinical domains.
  ○ There was no clear association between followup duration and correlation value for either active treatments or no treatment groups; however, correlation values were statistically significantly lower with increasing sample size of no treatment groups, but not active treatment groups.
- The choice of imputed correlation values can have a substantial impact on the estimate of the within-group and net-change SEs. Not unexpectedly, the difference between SEs calculated using complete study data versus those based on imputed correlation values depends on the difference of the imputed value from the study estimate of the correlation.
- In simulation studies of meta-analyses with different “true” correlation values across a number of representative scenarios we found that:
  ○ Imputation of any value for the within-group correlation parameter does not result in bias in the estimation of the meta-analyzed summary treatment effect.
  ○ The imputed value affects the coverage probability of the meta-analytic summary estimate: imputing values larger than the “true” value produces coverage lower than that attained with complete data; imputing values lower than the “true” value produces coverage greater than that attained with complete data. However, the DerSimonian-Laird meta-analytic estimator often has poor coverage in the presence of moderate to large heterogeneity; thus, the impact of different imputed correlation values has a relatively small effect on coverage in settings of heterogeneous meta-analyses.
  ○ Accuracy, as represented by MSE, was not appreciably impacted by the specific imputation approach.